# Acronyms

ABG: Air-Bone Gap
AHRQ: Agency for Healthcare Research and Quality
AOM: acute otitis media
CAM: complementary and alternative medicine
CI: confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CDLM: contact diode laser for myringotomy
CER: comparative effectiveness review
CT: computed tomography
dB: decibals
EHC: effective health care
EMBASE: Excerpta Medica Database
ENT: Ear, Nose and Throat
EPC: Evidence-based practice center
FU: follow-up
G: group
HL: hearing level
KQ: key question
MA: meta-analysis
MEE: middle ear effusion
MeSH: medical subject headings
mos: months
MA: meta-analysis
NA: not applicable
NICE: National Institute for Health and Clinical Excellence
NIDCD: National Institute on Deafness and Other Communication Disorders
NRCT: nonrandomized controlled trial
NR: not reported
ns: not significant
OME: otitis media with effusion
PE: pressure equalization
PICOTS: populations, interventions, comparators, outcomes, timeframes, and settings
PRISMA: Preferred Reporting Items for Systematic Review and Meta-analyses
PTA: pure-tone audiometry
RCT: randomized controlled trial
RR: relative risk
SIP: scientific information packet
SOE: strength of evidence
SR: systematic review
SRT: speech recognition threshold
TEP: technical expert panel
TM: tympanic membrane
TT: tympanostomy tubes
VT: ventilation tube
WW: watchful waiting