# Glossary

Acute otitis media: An acute infection of the middle ear that can be viral and/or bacterial in origin.
Audiometry: The testing of hearing ability that includes determination of the hearing levels, ability to discriminate between various sound intensities, ability to distinguish speech from background noise and other aspects. Pure tone audiometry and impedance audiometry (tympanometry) are two of the commonly used tests for audiometric evaluation.
Autoinflation: A technique whereby the Eustachian tube (the tube that connects the middle ear and the back of the nose) is reopened by raising pressure in the nose. This can be achieved by forced exhalation with closed mouth and nose, blowing up a balloon through each nostril or using an anesthetic mask. The aim is to introduce air into the middle ear, via the Eustachian tube, equalizing the pressures and allowing better drainage of the fluid.
Myringotomy: A surgical procedure in which an incision is made in the tympanic membrane. It may be performed as a single procedure or as a preparation for insertion of a tympanostomy tube.
Otitis media with effusion: A collection of fluid in the middle ear without signs or symptoms of ear infection.
Otoscopy: The clinical examination of the ear canal and tympanic membrane, usually by means of a hand-held auriscope (also known as an otoscope) providing illumination and magnification. Sometimes an attachment is used that permits insufflation of air into the ear canal so that the mobility of the tympanic membrane can be assessed, and this is known as pneumatic otoscopy.
Tympanogram: A curve showing the transmission of energy through the middle ear at various air pressures in the external auditory canal. It gives a crude but objective assessment of conductive hearing loss, and various middle ear disorders yield distinctive patterns of tympanogram:
  - Tympanogram A: a symmetrical triangular graph with its peak at zero pressure level represents normal middle ear function.
  - Tympanogram B: a flat line on the graph represents the middle ear space filled with fluid, restricting movement of the tympanic membrane under the externally applied pressure.
  - Tympanogram C: this pattern is found when there is a reduction of middle ear pressure relative to the air pressure in the external auditory canal, which causes inward retraction of the tympanic membrane; the graph shows the shift of the tympanographic peak into the negative value range, but it is of a normal shape.
Tympanometry: Also known as impedance audiometry, the test measures how readily the middle ear system (the tympanic membrane and the middle ear ossicles) can be set into vibration with a change of air pressure in the external auditory canal. In the normal ear, maximum sound transmission occurs when the air pressure within the middle ear space is the same as the atmospheric pressure, that is, equal to the air pressure in the external auditory canal.
Watchful waiting: Watchful waiting or active observation, as it has more recently been called, is the process of regular review and followup of the child, including assessments of hearing, development, and educational progress.