# Detailed Strength of Evidence Tables

## Key Question 1

### Clinical Outcomes

#### Tympanostomy Tubes Versus Other Tympanostomy Tube or Variation in Tympanostomy Tube Insertion Technique

Table F-1 Detailed strength of evidence grading table, tube retention

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT v. TT + N-acetylcysteine addition, mean time | 1; 75 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference
Shah Teflon tube +aspiration v. shah Teflon tube no aspiration, 3–24 mo | 1; 55 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference
Permavent silicone Shah v. polyethelyne Shah, TT, 1 yr | 1; 25 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference
Goode silicon TT v. Teflon Armstrong TT, 1 yr | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference
Phosphorylcholine-coated fluoroplastic Armstrong TT v. uncoated Armstrong TT, 2 yrs | 1; 70 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference
Goode silicon TT v. Teflon Armstrong TT, 3–5 yrs | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study,

Abbreviations: TT = tympanostomy tubes; v. = versus.

Table F-2 Detailed strength of evidence grading table, OME recurrence

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Shorter-term v longer-term TT, recurrence of OME | 4, 747 | Medium | Consistent | Direct | Imprecise | Low, OME recurrence higher in shorter-term TT after one year
Shah v. mini-shah tube | 1, 116 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, Shah better
Teflon Shepard TT vs. silicone Goode TT vs. Silicone Paparella TT | 1; 220 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single observational study, silicone best
Permavent silicone Shah v. polyethelyne Shah | 1; 25 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, statistical difference not reported

Abbreviations: MEE, middle ear effusion; TT, tympanostomy tubes; yr, year.

Table F-3 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Goode silicon TT v. Teflon Armstrong TT, mean hearing loss, mean time | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single study, statistical difference not reported

Abbreviations: TT = tympanostomy tubes; v. = versus.

Table F-4 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: TT = tympanostomy tubes; vs. = versus.

#### Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

Table F-5 Detailed strength of evidence grading table, middle ear effusion and time with effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. WW or delayed treatment, Time with MEE or OME,1 yr, | MA 3, 574 1 study, 119 | Medium | Consistent | Direct | Precise | High 32% less time with MEE, sig less % time with OME, favors TT
TT vs. myr, Time with MEE, 1 yr | 2 studies, 294 | Medium | Consistent | Direct | Imprecise | Low for benefit, favoring TT
TT vs. WW or myr, Time with MEE or OME, 2 yrs | MA:3, 426 | Medium | Consistent | Direct | Precise | Moderate 13% less time with MEE, MA favors TT
TT, Time with OME, 3 yrs | 1 study, 119 | Medium | Unknown, 1 study | Direct | Imprecise | Insufficient, one study found no diff

Abbreviations: MEE = middle ear effusion; myr = myringotomy TT = tympanostomy tubes; WW = watchful waiting; yr = year.

Table F-6 Detailed strength of evidence grading table, OME recurrence and ventilation

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: MEE, middle ear effusion; TT, tympanostomy tubes

Table F-7 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, episodes/person yr, 3 yrs | 1, 119 | Medium | Unknown, single study | Direct | Imprecise | Insufficient: one study found no diff

Abbreviations: TT = tympanostomy tubes.

Table F-8 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, Hearing Levels by ear, 4–6 mos | MA: 3, 230 ears | Medium | Consistent | Direct | Precise | High, 10.1 dB better with TT
TT, Hearing Levels by child, up to 9 mos | MA: 3, 523 Study:1, 248 | Medium | Consistent | Direct | Precise | High 4.2 dB better with TT
TT, Hearing levels by ear, 7–12 mos | MA: 3, 234 | Medium | Consistent | Direct | Imprecise | Low, no difference −5.18 (95% CI, −10.43 to 0.07)
TT, Hearing Levels by child, 12 mos | MA: 2, 328 | Medium | Inconsistent | Direct | Precise | Low, no difference −0.41 dB (95% CI, −2.37 to 1.54)
TT, Hearing Levels by child, 18 mos | MA: 2, 283 | Medium | Inconsistent | Direct | Precise | Low, no difference −0.02 dB (95% CI, −3.22 to 3.18)
TT, Hearing Levels by ear, 24 mos | 1 study, 72 ears | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study, no difference

Abbreviations: TT = tympanostomy tubes; v. = versus.

##### Tympanostomy Tubes and Adenoidectomy Versus Myringotomy and Adenoidectomy or Adenoidectomy Alone

Table F-9 Detailed strength of evidence grading table, reoccurrence of middle ear effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno v. myring + adeno, Time with MEE or OME, 1 yrs | 1;42 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference
TT+adeno v adeno, Time with MEE or OME,5 yr, | 1; 55 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference

Abbreviations: MEE, middle ear effusion; TT, tympanostomy tubes; yr, year

Table F-10 Detailed strength of evidence grading table, Ventilation maintained

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno v. laser myro+adeno, episodes/person yr, 3 mo | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, one small study favoring TT

Abbreviations: TT, tympanostomy tubes; yr, year.

Table F-11 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno, episodes/person yr, 3 yrs | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: TT, tympanostomy tubes; yr, year.

Table F-12 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno v. adeno, Hearing Levels, 3 mos | 1; 55 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, one small study favoring TT
TT+adeno v. myring +adeno, Hearing Levels, 6 mos, 12 mo and >3 years | 6 studies: 3 RCTs by person (N=431) 2 RCTs (by ears) (N=338) 1 NRCT (by ears) (N=193)3, 160 | Medium | Consistent | Direct | Imprecise | Low, no difference
TT+adeno v. myring +adeno, Hearing levels,12 mo | 2;130 | Medium | Consistent | Direct | Imprecise | Insufficient, no difference in 2 small studies
TT+adeno v. myring+adeno, Hearing Levels, 2 years | 1, 146 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference in 1 small study
TT+adenoid v. myring+adeno/adenoid alone, Hearing Levels >3 years | 2; 201 | Medium | Consistent | Direct | Imprecise | Low, no difference

Abbreviations: TT, tympanostomy tubes; yr, year.

#### Myringotom Comparisons

Table F-13 Detailed strength of evidence grading table, resolution of OME

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy, resolution of OME | 1, 60 | Medium | Unknown, single study | Direct | Imprecise | Insufficient

Table F-14 Detailed strength of evidence grading table, OME recurrence and ventilation

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

Table F-15 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

Table F-16 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy, air-bone gap improvement (3mos) | 1, 60 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference, one small study

#### Myringotomy and Adenoidectomy Comparisons

Table F-17 Detailed strength of evidence grading table, middle ear effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy, % with middle ear effusion, post-op | 1, 87 ears^*^ | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference, one small study

* number analyzed

Table F-18 Detailed strength of evidence grading table, OME recurrence and ventilation

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy, patency of ears, post-op | 1, 87 ears^*^ | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single smallstudy

* number analyzed

Table F-19 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

Table F-20 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

#### Adenoidectomy Versus Other Interventions

Table F-21 Detailed strength of evidence grading table, middle ear effusion and time with effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy (+unilateral TT) vs no treatment, OME resolution 6 mos | MA otoscopy:2, 153 MA tympanometry: MA: 3, 297 | Medium | Consistent | Direct | Precise | High Otoscopy: Risk Diff: 0.27 Tympanometry: Risk diff: 0.22
Adenoidectomy (+ unilateral TT), OME resolution by tympanometry), 12 mos | MA: 3, 298 | Medium | Consistent | Direct | Precise | High Risk diff: 0.29
Adenoidectomy+ myringotomy vs. myringotomy, 2 years | 1 study (N=237) | Medium | Unknown, single study | Direct | Precise | Low, less time with effusion in adenoidectomy arm

Table F-22 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy vs no intervention, Change in hearing level, 6 mos, 12 mos | 2 studies (N=302) | Medium | Inconsistent | Direct | Imprecise | Insufficient, mixed results
Adenoidectomy+ myringotomy vs. myringotomy, 2 years | 1 study (N=237) | Medium | Unknown, single study | Direct | Precise | Low, less time with reduced hearing in adenoidectomy arm

#### Steroids Versus Control

Table F-23 Detailed strength of evidence grading table, middle ear effusion and time with effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Oral, 1–2 mo, persisting | MA 3, 106 | Medium | Consistent | Direct | Imprecise | Low: no difference
Oral (+antibiotic), 1–2 mo, persisting | MA 3, 243 | Medium | Consistent | Direct | Precise | Moderate: no difference
Topical, 1–2 mo | No studies | NA | NA | NA | NA | Insufficient: no evidence
Topical, cure rate, 3 & 9 mo | 1, 217 | Low | Unknown, single study | Direct | Precise | Low: no difference
Topical (+antibiotic), persisting, 6 mo | 1, 59 | Medium | Unknown, single study | Direct | Imprecise | Insufficient: no difference
Oral (+antibiotic), persisting, 6 mo | 1, 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient: no difference

Table F-24 Detailed strength of evidence grading table, OME recurrence and ventilation

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical | No studies | NA | NA | NA | NA | Insufficient: no evidence
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-25 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical | No studies | NA | NA | NA | NA | Insufficient: no evidence
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-26 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical, 1–2 mo | No studies | NA | NA | NA | NA | Insufficient: no evidence
Topical,> 3 mo | 1, 217 | Medium | Unknown, single study | Direct | Precise | Low: no difference
Oral, 1–2 mo | 1, 49 | Low | Unknown, single study | Direct | Imprecise | Insufficient: no difference
Oral, 3+ mo | No studies | NA | NA | NA | NA | Insufficient: no evidence

#### Autoinflation Versus Control

Table F-27 Detailed strength of evidence grading table, middle ear effusion and time with effusion

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation, improvement in tympanogram ≤ 1 mo | MA:2, 185 | Medium | Consistent | Direct | Precise | Low, > improvement with autoinflation RR: 2.71
Autoinflation, improvement in tympanogram > 1 mo | MA:2, 185 | Medium | Consistent | Direct | Imprecise | Insufficient, no difference
Autoinflation, (3 wks and 3 mos) | No studies | NA | NA | NA | NA | Insufficient, no evidence
Autoinflation, 4 wks post tx and end of tx | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable.

Table F-28 Detailed strength of evidence grading table, OME recurrence and ventilation

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable.

Table F-29 Detailed strength of evidence grading table, AOM

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable.

Table F-30 Detailed strength of evidence grading table, measured hearing

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation, ≤ 1 mo | No studies | NA | NA | NA | NA | Insufficient, no evidence
Autoinflation, >1 mo | No studies | NA | NA | NA | NA | Insufficient, no evidence
Autoinflation, end of tx improvement in PTA, post tx (3 wks and 3 mos) | MA:2, 125 | Medium | Inconsistent | Direct | Imprecise | Insufficient, no difference
Autoinflation, PTA, 4 wks post tx and end of tx | MA 2, 179 | Medium | Inconsistent | Direct | Imprecise | Insufficient, no difference

Abbreviations: Mo, month; PTA, pure tone average; tx, treatment; wks, weeks.

## Key Question 2

### Functional Outcomes

#### Tympanostomy Tubes Versus Other Tympanostomy Tube or Variation in Tympanostomy Tube Insertion Technique

Table F-31 Detailed strength of evidence grading table, speech, language and cognitive development

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: mos = months; NA = not applicable; TT = tympanostomy tubes; vs. = versus.

Table F-32 Detailed strength of evidence grading table, behavior

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: TT = tympanostomy tubes; vs. = versus.

Table F-33 Detailed strength of evidence grading table, quality-of-life

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable; TT = tympanostomy tubes; vs. = versus.

Table F-34 Detailed strength of evidence grading table, satisfaction with care

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable; TT = tympanostomy tubes; vs. = versus.

#### Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

Table F-35 Detailed strength of evidence grading table, speech, language and cognitive development

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, Language Comprehension, 6–9 mos or at preschool and elementary school age | MA: 3, 394 + 2 RCT, 503 | Medium | Inconsistent | Direct | Precise | Moderate, no difference
TT, Language Expression, 6–9 mos | MA:3, 393 | Low | Inconsistent | Direct | Precise | Low, no difference
TT, Cognitive Development, 9 mos | 2 RCTs, 503 | Medium | Consistent | Direct | Imprecise | Low, no difference
TT, Academic Achievement, elementary school age | 2 RCTs, 503 | Medium | Consistent | Direct | Imprecise | Low, no difference
TT, Cognitive Development, 3 yrs | 1 study, 393 | Low | Unknown, single study | Direct | Precise | Insufficient, no difference

Abbreviations: mos = months; TT = tympanostomy tubes; yrs = years.

Table F-36 Detailed strength of evidence grading table, behavior

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, Behavior, 6, 12 mos | 1 study, 176, 165 | Low | Unknown, single study | Direct | Imprecise | Insufficient, no difference
TT, Behavior, 9, 12 mos | 1 study, 182 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, conflicting evidence
TT, Behavior. 3 yrs | 1 study, 393 | Low | Unknown, single study | Direct | Imprecise | Insufficient, no difference

Abbreviations: mos = months; TT = tympanostomy tubes; yrs = years.

Table F-37 Detailed strength of evidence grading table, quality-of-life

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, Quality of Life, 6, 12 mos | 1, 176, 165 | Low | Unknown, single study | Direct | Imprecise | Insufficient: no difference

Abbreviations: mos = months; TT = tympanostomy tubes.

Table F-38 Detailed strength of evidence grading table, satisfaction with care

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable; TT = tympanostomy tubes.

#### Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

Table F-39 Detailed strength of evidence grading table, speech, language and cognitive development

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable; TT = tympanostomy tubes.

Table F-40 Detailed strength of evidence grading table, behavior

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno, | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: adeno = adenoidectomy; NA = not applicable; TT, tympanostomy tubes.

Table F-41 Detailed strength of evidence grading table, quality-of-life

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno vs. myring+adeno, quality of Life, 6 mos | 1; 52 | Medium | Unknown, single study | Direct | Precise | Insufficient: no difference
TT+adeno v. myring+adeno, Quality of Life, 12 mos | 1, 52 | Medium | Unknown, single study | Direct | Precise | Insufficient: no difference

Abbreviations: adeno = adenoidectomy; myring = myringotomy; mos, months; TT, tympanostomy tubes.

Table F-42 Detailed strength of evidence grading table, satisfaction with care

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: adeno = adenoidectomy; NA = not applicable.

#### Myringotomy Comparisons

Table F-43 Detailed strength of evidence grading table, all functional outcomes

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable; vs. = versus.

#### Myringotomy With Adenoidectomy Comparisons

Table F-44 Detailed strength of evidence grading table, all functional outcomes

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable; vs. = versus.

#### Adenoidectomy Versus Other Interventions

Table F-45 Detailed strength of evidence grading table, speech, language and cognitive development

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-46 Detailed strength of evidence grading table, behavior

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-47 Detailed strength of evidence grading table, quality-of-life

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-48 Detailed strength of evidence grading table, satisfaction with care

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

#### Steroids Versus Control

Table F-49 Detailed strength of evidence grading table, speech, language and cognitive development

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical vs control, 3 and 9 mos | 1, 144 | Medium | Unknown, 1 study | Direct | Imprecise | No difference in parent-reported hearing difficulties
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: Mos = months; NA = not applicable; vs. = versus.

Table F-50 Detailed strength of evidence grading table, behavior

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical | No studies | NA | NA | NA | NA | Insufficient: no evidence
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

Table F-51 Detailed strength of evidence grading table, quality-of-life

Intervention, time to outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical, <3 mos | 1, 39 | Medium | Unknown, single study | Direct | Imprecise | Insufficient: no difference
Topical, ≥3 mos | 1, 144 | Low | Unknown, single study | Direct | Imprecise | Low, no difference
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: mos = months; NA = not applicable

Table F-52 Detailed strength of evidence grading table, satisfaction with care

Intervention, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical | No studies | NA | NA | NA | NA | Insufficient: no evidence
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

Abbreviations: NA = not applicable.

### Autoinflation Versus Control

Table F. 53 Detailed strength of evidence grading table, all measures

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation, any time period | No studies | NA | NA | NA | NA | Insufficient, no evidence

Abbreviations: NA = not applicable.

## Key Question 3

### Harms or Tolerability

#### Tympanostomy Tubes Versus Other Tympanostomy Tube or Variation in Tympanostomy Tube Insertion Technique

Table F-54 Detailed strength of evidence grading table, harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Goode silicon TT v. Teflon Armstrong TT, Repeat TT; repeat TT placement | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single mall study
TT v. TT + NAC addition, repeat tube placement, 29 mo; repeat TT placement | 1; 75 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study
TT v TT, otorrhea | 1 RCT, 30 ears; 2 obs, 779 ears | Medium | Consistent | Direct | Imprecise | Low for harms from longer-term TT
TT v TT, perforation | 3; 305 | Medium | Inconsistent | Direct | Imprecise | Insufficient, mixed results
TT v TT, cholesteatoma | 2; 235 | Medium | Inconsistent | Direct | Imprecise | Insufficient, no difference
TT v TT, tympanosclerosis | 3; 196 | Medium | Inconsistent | Direct | Imprecise | Insufficient, mixed results
TT v TT, Occlusion | 1; 70 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, single small study
TT v TT, Granulation | 2; 290 | Medium | Inconsistent | Direct | Imprecise | Insufficient, mixed results

#### Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

Table F-55 Detailed strength of evidence grading table, harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT, Tx Failure, 3 yrs | 1 study, 109 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference
TT, Otorrhea, various | 4 studies, 960 | Medium | Consistent | Direct | Imprecise | Low, higher in TT group
TT, Atrophy, various | 4 studies, 1024 | Medium | Inconsistent | Direct | Imprecise | Insufficient, mixed results
TT, Perforation, various | 3 studies, 466 | Medium | Consistent | Direct | Imprecise | Insufficient, mixed results
TT, Tympanosclerosis, various | 5 studies, 1129 | Medium | Consistent | Direct | Imprecise | Low, higher in TT group
TT, Cholesteatoma, various | 2 studies, 220 | Medium | Consistent | Direct | Imprecise | Insufficient, no difference
Time with granulation | 1 study, 150 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, 1 study

#### Tympanostomy Tubes and Adenoidectomy Versus Myringotomy and Adenoidectomy or Adenoidectomy Alone

Table F-56 Detailed strength of evidence grading table, harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno, Tx Failure, 3 yrs | 1; 25 | Medium | Unknown, single study | Direct | Precise | Insufficient, single studies
TT+adeno v. myring+adeno, Otorrhea, various | 3; 87 | Medium | Inconsistent | Direct | Precise | Insufficient, mixed results
TT+adeno, Atrophy, Various | No studies | NA | NA | NA | NA | Insufficient: no evidence
TT+adeno v. myring+adeno, Perforation, Various | 1; 15 | Medium | Unknown, single study | Direct | Imprecise | Insufficient; no difference
TT+adeno v. adeno alone or with myring, Tympanosclerosis, various | 3; 485 | Medium | Consistent | Direct | Imprecise | Low, rates higher in TT group
TT+adeno, Cholesteatoma, various | No studies | NA | NA | NA | NA | Insufficient: no evidence
Granulation | No studies | NA | NA | NA | NA | Insufficient: no evidence

#### Myringotomy Comparisons

Table F-57 Detailed strength of evidence grading table, all harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

##### Myringotomy With Adenoidectomy Comparisons

Table F-58 Detailed strength of evidence grading table, all harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

#### Adenoidectomy Versus Other Interventions

Table F-59 Detailed strength of evidence grading table, harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy vs. other treatments | 2, 739 | Medium | Consistent | Direct | Imprecise | Rare but possible chance of post-surgical hemorrhage.

#### Steroids Versus Control

Table F-60 Detailed strength of evidence grading table, harms

Intervention, outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical, serious | 3, 323 | Medium | Consistent | Direct | Imprecise | Insufficient No events
Oral, serious | 5, subjects: NR | Medium | Consistent | Direct | Imprecise | Insufficient No events
Topical, mild | 1, 170 | Medium | Unknown, single study | Direct | Imprecise | Low, no difference
Oral, mild | 2, subjects: NR | Low | Consistent | Direct | Imprecise | Insufficient: no difference

#### Autoinflation Versus Control

Table F-61 Detailed strength of evidence grading table, harms

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation | No studies | NA | NA | NA | NA | Insufficient, no evidence

## Key Question 4

### Patient Subgroups

#### Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

Table F-62 Detailed strength of evidence grading table, sleep apnea

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+ adenoid v. myrin + adenoid, hearing, 6,12 mos. | 1, 52 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, no difference, one small study
TT+ adenoid v. myrin + adenoid, quality of life, 6,12 mos. | 1, 52 | Medium | Unknown, single study | Direct | Imprecise | Insufficient, mixed findings, one small study

#### Autoinflation Versus Control

Table F-63 Detailed strength of evidence grading table, adults

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation, improvement in middle ear status end of tx. 50 days post tx | 1, 198 | Medium | Unknown, single study | Direct | Imprecise | Low Magnitude of difference 44 to 47%

## Key Question 5

### Health Care Factors

#### Tympanostomy Tubes Versus Other Tympanostomy Tube or Variation in Tympanostomy Tube Insertion Technique

Table F-64 Detailed strength of evidence grading table, health care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT vs. TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

#### Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

Table F-65 Detailed strength of evidence grading table, health care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT | No studies | NA | NA | NA | NA | Insufficient: no evidence

#### Tympanostomy Tubes and Adenoidectomy Versus Adenoidectomy Alone or With Other Intervention

Table F-66 Detailed strength of evidence grading table, health care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
TT+adeno | No studies | NA | NA | NA | NA | Insufficient: no evidence

#### Myringotomy Comparisons

Table F-67 Detailed strength of evidence grading table, all heath care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy + Mitomycin C vs. myringotomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

##### Myringotomy and Adenoidectomy Comparisons

Table F-68 Detailed strength of evidence grading table, all heath care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Myringotomy (laser) with adenoidectomy vs. Myringotomy (cold knife) with adenoidectomy | No studies | NA | NA | NA | NA | Insufficient, no evidence

### Adenoidectomy Versus Other Interventions

Table F-69 Detailed strength of evidence grading table, health care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Adenoidectomy | No studies | NA | NA | NA | NA | Insufficient: no evidence

### Steroids Versus Control

Table F-70 Detailed strength of evidence grading table, health care factors

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Topical | No studies | NA | NA | NA | NA | Insufficient: no evidence
Oral | No studies | NA | NA | NA | NA | Insufficient: no evidence

### Autoinflation Versus Control

Table F-71 Detailed strength of evidence grading table, all outcomes

Intervention, Outcome, Time to Outcome | Number of Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Grade Magnitude of Effect
Autoinflation, any time period | No studies | NA | NA | NA | NA | Insufficient, no evidence