# Risk-of-Bias Tables

Table E-1 Risk of bias: RCTs and NRCTs

Table E-2 Risk of bias: Observational

Table E-3 Risk of bias of systematic reviews using AMSTAR questions22

Table E-4 High risk of bias: RCTs and NRCTs

Table E-5 High risk of bias: Observational

## References

1 Abdullah VA, Pringle MB, Shah NS. Use of the trimmed Shah permavent tube in the management of glue ear. J Laryngol Otol. Apr. 1994;108(4):303-6. [pmid: 8182314].
2 Austin DF. Adenotonsillectomy in the treatment of secretory otitis media. Ear Nose Throat J. Jun. 1994;73(6):367-9. 73. 4. [pmid: 8076535].
3 Brown MJ, Richards SH, Ambegaokar AG. Grommets and glue ear: a five-year follow up of a controlled trial. J R Soc Med. May. 1978;71(5):353-6. [pmid: 650647].
4 D'Eredità R, Shah UK. Contact diode laser myringotomy for medium-duration middle ear ventilation in children. Int J Pediatr Otorhinolaryngol. 2006:1077-80. [pmid: 16406076].
5 Koopman JP, Reuchlin AG, Kummer EE, et al. Laser myringotomy versus ventilation tubes in children with otitis media with effusion: a randomized trial. Laryngoscope. May. 2004;114(5):844-9. [pmid: 15126741].
6 Licameli G, Johnston P, Luz J, et al. Phosphorylcholine-coated antibiotic tympanostomy tubes: are post-tube placement complications reduced?. Int J Pediatr Otorhinolaryngol. Sep. 2008;72(9):1323-8. [pmid: 18635268].
7 Lildholdt T. Unilateral grommet insertion and adenoidectomy in bilateral secretory otitis media: preliminary report of the results in 91 children. Clin Otolaryngol Allied Sci. Apr. 1979;4(2):87-93. [pmid: 455774].
8 Mandel EM, Rockette HE, Bluestone CD, et al. Myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Arch Otolaryngol Head Neck Surg. Oct. 1989;115(10):1217-24. [pmid: 2789777].
9 McRae D, Gatland DJ, Youngs R, et al. Aspiration of middle ear effusions prior to grommet insertion an etiological factor in tympanosclerosis. J Otolaryngol. Aug. 1989;18(5):229-31. [pmid: 2769837].
10 Ovesen T, Felding JU, Tommerup B, et al. Effect of N-acetylcysteine on the incidence of recurrence of otitis media with effusion and re-insertion of ventilation tubes. Acta Otolaryngol Suppl. 2000;543:79-81. [pmid: 10908985].
11 Popova D, Varbanova S, Popov TM. Comparison between myringotomy and tympanostomy tubes in combination with adenoidectomy in 3–7-year-old children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. Jul. 2010;74(7):777-80. [pmid: 20399511].
12 Ragab SM. The effect of radiofrequency and mitomycin C on the closure rate of human tympanostomy. Otol Neurotol. May. 2005;26(3):355-60. [pmid: 15891633].
13 Shishegar M, Hoghoghi H. Comparison of adenoidectomy and myringotomy with and without tube placement in the short term hearing status of children with otitis media with effusion: a preliminary report. Iranian Journal of Medical Sciences. 2007:169-72.
14 Tos M, Stangerup SE. Hearing loss in tympanosclerosis caused by grommets. Arch Otolaryngol Head Neck Surg. Aug. 1989;115(8):931-5. [pmid: 2751852].
15 Vlastos IM, Houlakis M, Kandiloros D, et al. Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol. Mar. 2011;125(3):274-8. [pmid: 21205368].
16 Wielinga EW, Smyth GD. Comparison of the Goode T-tube with the Armstrong tube in children with chronic otitis media with effusion. J Laryngol Otol. Aug. 1990;104(8):608-10. [pmid: 2230552].
17 Williamson I, Benge S, Barton S, et al. Topical intranasal corticosteroids in 4–11 year old children with persistent bilateral otitis media with effusion in primary care: double blind randomised placebo controlled trial. BMJ. 2009;339:b4984. [pmid: 20015903].
18 Williamson I, Benge S, Barton S, et al. A double-blind randomised placebo-controlled trial of topical intranasal corticosteroids in 4- to 11-year-old children with persistent bilateral otitis media with effusion in primary care. Health Technol Assess. Aug. 2009;13(37):1-144. [pmid: 19671372].
19 Szeremeta W, Parameswaran MS, Isaacson G. Adenoidectomy with laser or incisional myringotomy for otitis media with effusion. Laryngoscope. Mar. 2000;110(3 Pt 1):342-5. [pmid: 10718416].
20 Slack RW, Gardner JM, Chatfield C. Otorrhoea in children with middle ear ventilation tubes: a comparison of different types of tubes. Clin Otolaryngol Allied Sci. Oct. 1987;12(5):357-60. [pmid: 3427799].
21 Iwaki E, Saito T, Tsuda G, et al. Timing for removal of tympanic ventilation tube in children. Auris Nasus Larynx. Dec. 1998;25(4):361-8. [pmid: 9853658].
22 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
23 Browning GG, Rovers MM, Williamson I, et al. Grommets (ventilation tubes) for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2010;(10):CD001801. [pmid: 20927726].
24 van den Aardweg MT, Schilder AG, Herkert E, et al. Adenoidectomy for otitis media in children. Cochrane Database Syst Rev. 2010;(1):CD007810. [pmid: 20091650].
25 Perera R, Haynes J, Glasziou P, et al. Autoinflation for hearing loss associated with otitis media with effusion. Cochrane Database Syst Rev. 2006;(4):CD006285. [pmid: 17054290].
26 Thomas CL, Simpson S, Butler CC, et al. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2006;(3):CD001935. [pmid: 16855980].
27 Hellstrom S, Groth A, Jorgensen F, et al. Ventilation tube treatment: a systematic review of the literature. Otolaryngol Head Neck Surg. Sep. 2011;145(3):383-95. [pmid: 21632976].
28 Simpson Sharon A, Lewis R, van der Voort J, et al. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
29 Black N, Crowther J, Freeland A. The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial. Clin Otolaryngol Allied Sci. Jun. 1986;11(3):149-55. [pmid: 3524910].
30 Black NA, Sanderson CF, Freeland AP, et al. A randomised controlled trial of surgery for glue ear. BMJ. Jun. 16. 1990;300(6739):1551-6. [pmid: 2196954].
31 Gates GA, Avery CA, Prihoda TJ. Effect of adenoidectomy upon children with chronic otitis media with effusion. Laryngoscope. Jan. 1988;98(1):58-63. [pmid: 3336263].
32 Gibson PG, Stuart JE, Wlodarczyk J, et al. Nasal inflammation and chronic ear disease in Australian Aboriginal children. J Paediatr Child Health. Apr. 1996;32(2):143-7. [pmid: 8860389].
33 Honjo I, Fujita A, Kurata K, et al. Significance of adenoidectomy in the treatment of secretory otitis media. Adv Otorhinolaryngol. 1992;47:246-50. [pmid: 1456142].
34 Ruckley RW, Blair RL. Thermal myringotomy (an alternative to grommet insertion in childhood secretory otitis media?). J Laryngol Otol. Feb. 1988;102(2):125-8. [pmid: 3346587].
35 Yagi HI. The surgical treatment of secretory otitis media in children. J Laryngol Otol. Mar. 1977;91(3):267-70. [pmid: 321716].
36 Caye-Thomasen P, Stangerup SE, Jorgensen G, et al. Myringotomy versus ventilation tubes in secretory otitis media: eardrum pathology, hearing, and eustachian tube function 25 years after treatment. Otol Neurotol. Aug. 2008;29(5):649-57. [pmid: 18520632].
37 Tos M, Bonding P, Poulsen G. Tympanosclerosis of the drum in secretory otitis after insertion of grommets. A prospective, comparative study. J Laryngol Otol. Jun. 1983;97(6):489-96. [pmid: 6683295].
38 Karlan MS, Skobel B, Grizzard M, et al. Myringotomy tube materials: bacterial adhesion and infection. Otolaryngol Head Neck Surg. Nov–Dec. 1980;88(6):783-94. [pmid: 7208047].
39 Moller P, Dingsor G, Breck P, et al. Transtympanic ventilator tubes in the treatment of seromucous otitis. Indications and results. Rev Laryngol Otol Rhinol (Bord). 1992;113(5):389-95. [pmid: 1344560].
40 Tatar EC, Unal FO, Tatar I, et al. Investigation of surface changes in different types of ventilation tubes using scanning electron microscopy and correlation of findings with clinical follow-up. Int J Pediatr Otorhinolaryngol. Mar. 2006;70(3):411-7. [pmid: 16125252].
41 Zakirullah M, Saeedullah. Surgical management of Otitis Media with Effusion; A prospective study of 120 patients. J Postgrad Med Inst. 2001;15(2):165-70.
42 Bozkurt MK, Calguner M. The efficacy of CO2 laser myringotomy in serous otitis media. Kulak Burun Bogaz Ihtis Derg. 2004;12(3–4):55-9. [pmid: 16010101].
43 D'Eredita R. Contact diode laser myringotomy and mitomycin C in children. Otolaryngol Head Neck Surg. Jun. 2004;130(6):742-6. [pmid: 15195061].
44 Hassmann E, Skotnicka B, Baczek M, et al. Laser myringotomy in otitis media with effusion: long-term follow-up. Eur Arch Otorhinolaryngol. Jul. 2004;261(6):316-20. [pmid: 14551787].
45 Hornigold R, Morley A, Glore RJ, et al. The long-term effect of unilateral t-tube insertion in patients undergoing cleft palate repair: 20-year follow-up of a randomised controlled trial. Clin Otolaryngol. Jun. 2008;33(3):265-8. [pmid: 18559037].
46 Katz S, Schmelzer B, Van Rompaey D. Surgical management of chronic otitis media with effusion. Acta Otorhinolaryngol Belg. 1995;49(1):69-73. [pmid: 7725924].
47 Marshak G, Neriah ZB. Adenoidectomy versus tympanostomy in chronic secretory otitis media. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):316-8. [pmid: 6778336].
48 Matt BH, Miller RP, Meyers RM, et al. Incidence of perforation with Goode T-tube. Int J Pediatr Otorhinolaryngol. Feb. 1991;21(1):1-6. [pmid: 2037413].
49 Robinson PM. Secretory otitis media in the adult. Clin Otolaryngol Allied Sci. Aug. 1987;12(4):297-302. [pmid: 3665139].
50 Siegel GJ, Chandra RK. Laser office ventilation of ears with insertion of tubes. Otolaryngol Head Neck Surg. Jul. 2002;127(1):60-6. [pmid: 12161732].
51 Smyth GD, Patterson CC, Hall S. Tympanostomy tubes: do they significantly benefit the patient?. Otolaryngol Head Neck Surg. Nov–Dec. 1982;90(6):783-6. [pmid: 10994430].
52 Strachan D, Hope G, Hussain M. Long-term follow-up of children inserted with T-tubes as a primary procedure for otitis media with effusion. Clin Otolaryngol Allied Sci. Dec. 1996;21(6):537-41. [pmid: 9118577].
53 Yaman H, Guclu E, Yilmaz S, et al. Myringosclerosis after tympanostomy tube insertion: relation with tube retention time and gender. Auris Nasus Larynx. Dec. 2010;37(6):676-9. [pmid: 20392579].
54 Zanetti D, Piccioni M, Nassif N, et al. Diode laser myringotomy for chronic otitis media with effusion in adults. Otol Neurotol. Jan. 2005;26(1):12-8. [pmid: 15699714].