# Abstract and Full-Text Forms

The following are lists of fields used in the abstract and full text review forms. Please see the Evidence Tables (Appendix C) for fields used in the data abstraction forms.

Table D1 Abstract review form fields

REF ID
Author
Year
Title
Abstract
Is the publication original research and available in full text form (NOT editorials, letters, non-systematic reviews, abstract only material)? If no, X1.
Is the publication a controlled trial (randomized or non-randomized), a systematic review or meta-analysis, a cohort study (prospective or retrospective) or a case/control study? If no, X2.
Does the study present information in relation to a population with OME ? If no, X3.
Does the study present information in relation to an intervention of interest? If no, X4.
Does the study compare at least two of the interventions of interest? If no, X5.
Is the study published in the English language? If no X6.
Have met all previous inclusion criteria. Do any of the studies fall into the following categories (place appropriate X code)? Adenoidectomy for OME with a publication date before 2008? If yes, X7. Autoinflation for OME with a publication date before 2005? If yes, X8. Steroids for OME with a publication date before 2005? If yes, X9. Tympanostomy tubes for OME with a publication date before 2006? If yes, X10 Observational and case control studies for CAM? If yes, X11.
Background? (To suggest an abstract that would otherwise be excluded from the review for use as background information, mark it with BKG, along with EXC and the exclusion number/code. Use BKG judiciously!)
Comments: Please include a comment if you included an abstract, but did so do to a lack of clarity within the abstract. Explain why you think the FT will reveal that the study should be excluded.

Table D2 Full text review form fields

Ref ID
Authors
Year
Title
Is the publication original research and available in English and in full text form (NOT editorials, letters, non-systematic reviews, abstract only material)?
Is the publication a controlled trial (randomized or non-randomized), a cohort study (prospective or retrospective) or a case/control study?
Does the study present information in relation to a population with OME? Is the population being treated For OME (i.e., not a prevention study). If the population is mixed are the results stratified? Is the OME population a non-cancer population (i.e., not OME secondary to nasopharyngeal carcinoma)?
Does the study present information in relation to an intervention of interest (autoinflation, myringotomy, adenoidectomy, tympanostomy tubes, steroids, topical or nasal steroids, watchful waiting, variations in surgical techniques, or CAM)
Does the study compare at least two interventions listed above?
Adenoidectomy for OME: RCT of children with a publication date of 2008 or later?
Autoinflation for OME: RCT of children with with a publication date of 2005 or later?
Steroids for OME with a publication date of 2005 or later?
Tympanostomy Tubes for OME:RCT of children with a publication date of 2006 or later?
Randomized and non-randomized trials for CAM?
Comments
Does the study belong to a set of Companion Studies? (Yes/No)
Include citations of any Companion Studies here

AMSTAR: Risk of bias assessment for systematic reviews