# Evidence Tables

Evidence Table 1 Study characteristics

Evidence Table 2 Populations

Evidence Table 3 Interventions

Evidence Table 4 Benefits KQ 1 and 2, Part 1

Evidence Table 5 Benefits KQ 1 and 2, Part 2

Evidence Table 6 Subgroup analysis, Part 1

Evidence Table 7 Subgroup analysis, Part 2

Evidence Table 8 Harms, Part 1

Evidence Table 9 Harms, Part 2

Evidence Table 10 Study risk of bias: All studies

Evidence Table 11 Systematic reviews

## References

1 Bremner JD, Innis RB, Ng CK, et al. Positron emission tomography measurement of cerebral metabolic correlates of yohimbine administration in combat-related posttraumatic stress disorder. Arch Gen Psychiatry. Mar. 1997;54(3):246-54. [pmid: 9075465].
2 Hickling EJ, Blanchard EB. The private practice psychologist and manual-based treatments: post-traumatic stress disorder secondary to motor vehicle accidents. Behav Res Ther. Mar. 1997;35(3):191-203. [pmid: 9125099].
3 Hembree EA, Street GP, Riggs DS, et al. Do assault-related variables predict response to cognitive behavioral treatment for PTSD?. J Consult Clin Psychol. Jun. 2004;72(3):531-4. [pmid: 15279536].
4 D'Eredità R, Shah UK. Contact diode laser myringotomy for medium-duration middle ear ventilation in children. Int J Pediatr Otorhinolaryngol. 2006:1077-80. [pmid: 16406076].
5 Regehr C, Cadell S, Jansen K. Perceptions of control and long-term recovery from rape. Am J Orthopsychiatry. Jan. 1999;69(1):110-5. [pmid: 9990441].
6 Cox CE, Docherty SL, Brandon DH, et al. Surviving critical illness: acute respiratory distress syndrome as experienced by patients and their caregivers. Crit Care Med. Oct. 2009;37(10):2702-8. [pmid: 19865004].
7 Evans L, Cowlishaw S, Forbes D, et al. Longitudinal analyses of family functioning in veterans and their partners across treatment. J Consult Clin Psychol. Oct. 2010;78(5):611-22. [pmid: 20873897].
8 Hien DA, Cohen LR, Miele GM, et al. Promising treatments for women with comorbid PTSD and substance use disorders. Am J Psychiatry. Aug. 2004;161(8):1426-32. [pmid: 15285969].
9 Su TP, Lien TC, Yang CY, et al. Prevalence of psychiatric morbidity and psychological adaptation of the nurses in a structured SARS caring unit during outbreak: a prospective and periodic assessment study in Taiwan. J Psychiatr Res. Jan–Feb. 2007;41(1–2):119-30. [pmid: 16460760].
10 Turton P, Badenhorst W, Hughes P, et al. Psychological impact of stillbirth on fathers in the subsequent pregnancy and puerperium. Br J Psychiatry. Feb. 2006;188:165-72. [pmid: 16449705].
11 Hensley PL, Slonimski CK, Uhlenhuth EH, et al. Escitalopram: an open-label study of bereavement-related depression and grief. J Affect Disord. Feb. 2009;113(1–2):142-9. [pmid: 18597854].
12 Wald I, Shechner T, Bitton S, et al. Attention bias away from threat during life threatening danger predicts PTSD symptoms at one-year follow-up. Depress Anxiety. May. 2011;28(5):406-11. [pmid: 21381159].
13 Hall BJ, Hobfoll SE, Canetti D, et al. Exploring the association between posttraumatic growth and PTSD: a national study of Jews and Arabs following the 2006 Israeli-Hezbollah war. J Nerv Ment Dis. Mar. 2010;198(3):180-6. [pmid: 20215994].
14 Weiss DS, Marmar CR. Teaching Time-Limited Dynamic Psychotherapy for Posttraumatic-Stress-Disorder and Pathological Grief. Psychotherapy. Win. 1993;30(4):587-91.
15 Slack RW, Gardner JM, Chatfield C. Otorrhoea in children with middle ear ventilation tubes: a comparison of different types of tubes. Clin Otolaryngol Allied Sci. Oct. 1987;12(5):357-60. [pmid: 3427799].
16 Southwick SM, Morgan CA 3rd, Charney DS, et al. Yohimbine use in a natural setting: effects on posttraumatic stress disorder. Biol Psychiatry. Aug. 1. 1999;46(3):442-4. [pmid: 10435213].
17 Reist C, Kauffmann CD, Chicz-Demet A, et al. REM latency, dexamethasone suppression test, and thyroid releasing hormone stimulation test in posttraumatic stress disorder. Prog Neuropsychopharmacol Biol Psychiatry. May. 1995;19(3):433-43. [pmid: 7624494].
18 Vlastos IM, Houlakis M, Kandiloros D, et al. Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol. Mar. 2011;125(3):274-8. [pmid: 21205368].
19 Davidson J, Rothbaum BO, Tucker P, et al. Venlafaxine extended release in posttraumatic stress disorder: a sertraline- and placebo-controlled study. J Clin Psychopharmacol. Jun. 2006;26(3):259-67. [pmid: 16702890].
20 McLay RN, Wood DP, Webb-Murphy JA, et al. A randomized, controlled trial of virtual reality-graded exposure therapy for post-traumatic stress disorder in active duty service members with combat-related post-traumatic stress disorder. Cyberpsychol Behav Soc Netw. Apr. 2011;14(4):223-9. [pmid: 21332375].
21 Gottlieb JD, Mueser KT, Rosenberg SD, et al. Psychotic depression, posttraumatic stress disorder, and engagement in cognitive-behavioral therapy within an outpatient sample of adults with serious mental illness. Compr Psychiatry. Jan–Feb. 2011;52(1):41-9. [pmid: 21220064].
22 Hodgkinson PE, Shepherd MA. The impact of disaster support work. J Trauma Stress. Oct. 1994;7(4):587-600. [pmid: 7820351].
23 Williamson I, Benge S, Barton S, et al. Topical intranasal corticosteroids in 4–11 year old children with persistent bilateral otitis media with effusion in primary care: double blind randomised placebo controlled trial. BMJ. 2009;339:b4984. [pmid: 20015903].
24 Williamson I, Benge S, Barton S, et al. A double-blind randomised placebo-controlled trial of topical intranasal corticosteroids in 4- to 11-year-old children with persistent bilateral otitis media with effusion in primary care. Health Technol Assess. Aug. 2009;13(37):1-144. [pmid: 19671372].