# Excluded Studies

## Wrong Publication, Study Type, or Unavailable in English

1 Antibiotics for otitis media. Br Med J. Dec. 11. 1976;2(6049):1407. [pmid: 795497].
2 Surgery in chronic otitis media. Lancet. Jul. 16. 1977;2(8029):119-20. [pmid: 69199].
3 Surgical versus medical treatment for otitis media with effusion. N Y State J Med. 1991;91(11):516.
4 POEMs. Naturopathic ear drops work for ear pain... patient-oriented evidence that matters. JAAPA: Journal of the American Academy of Physician Assistants. 2003;16(8):19. Language: English. Entry Date: 20031205. Revision Date: 20051007. Publication Type: journal article.
5 Early tymp tubes do not improve outcomes after 3+ years. J Fam Pract. Nov. 2005;54(11):929. [pmid: 16299942].
6 Akyol MU. Ear, nose and throat disorders in children with Down syndrome. Laryngoscope. Jun. 2003;113(6):1089-90. [pmid: 12782832].
7 Akyol MU, Cengel S. The role of topical nasal steroid aerosol treatment in children with otitis media with effusion and/or adenoid hypertrophy. 12 months follow-up. Proceedings of the 9th International Conference on Pediatric Otorhinolaryngology (ESPO). Paris, France. 18–21 June 2006. 2006. Abstract No. 329.
8 Augustsson I, Nilsson C, Neander P. Do we treat "the right" children with secretory otitis media at the ENT clinic?. Acta Otolaryngol Suppl. 1988;449:39-40. [pmid: 3201954].
9 Baylor College of M. Postoperative analgesic and behavioral effects of intranasal fentanyl, intramuscular morphine and intravenous morphine in patients undergoing bilateral myringotomy and placement of ventilating tubes. ClinicalTrials.gov. accessed 25 July 2011. 2011. ClinicalTrials.gov ID: NCT01244126.
10 Bennett M, Warren F, Haynes D. Indications and Technique in Mastoidectomy. Otolaryngol Clin North Am. 2006;39(6):1095-113. [pmid: 17097435].
11 Berlin CM Jr. Advances in pediatric pharmacology and toxicology. Adv Pediatr. 1983;30:221-48. [pmid: 6424417].
12 Berman S. Long-term sequelae of ventilating tubes: implications for management of otitis media with effusion. Arch Pediatr Adolesc Med. Dec. 2005;159(12):1183-5. [pmid: 16330745].
13 Bisset A. Treatment of glue ear in general practice. Lancet. Jan. 11. 1997;349(9045):134. [pmid: 8996445].
14 Blom H. Efficacy of laser myringotomy versus ventilation tubes. Can we identify the eligible patient?. 5th European Congress of Oto-Rhino-Laryngology Head and Neck Surgery (EUFOS). Rhodes, Kos, Greece. 11–16 September, 2004. 2004:48. Abstract No. 280.
15 Bluestone CD. Otitis media in children: to treat or not to treat?. N Engl J Med. Jun. 10. 1982;306(23):1399-404. [pmid: 7043263].
16 Bluestone CD. Antimicrobial therapy for otitis media with effusion ("secretory" otitis media). Pediatr Ann. May. 1984;13(5):405-10. [pmid: 6539904].
17 Bluestone CD. Surgery for otitis media: results of randomized clinical trials as related to clinical practice. Adv Otorhinolaryngol. 1992;47:319-24. [pmid: 1456154].
18 Bluestone CD, Kenna MA. Chronic suppurative otitis media: antimicrobial therapy or surgery?. Pediatr Ann. May. 1984;13(5):417-21. [pmid: 6739180].
19 Bluestone CD, Klein JO, Paradise JL, et al. Workshop on effects of otitis media on the child. Pediatrics. Apr. 1983;71(4):639-52. [pmid: 6340046].
20 Bodner EE, Browning GG, Chalmers FT, et al. Can meta-analysis help uncertainty in surgery for otitis media in children. J Laryngol Otol. Oct. 1991;105(10):812-9. [pmid: 1753189].
21 Bojanovic M, Stankovic M, Dinic M, et al. Treatment of children with sectretory otitis media (SOM) with antihistamine and mucolytic or antibiotic (amoxicillin and clavulanic acic). XXII Annual Meeting of the Politzer Society: Otology 2000 - Achievements and Perspectives. Zurich, Switzerland. 15–19 August, 1999. 1999:28. Abstract No. A14-3.
22 Bomback F. Otitis media: Part II. Emergency and Office. Pediatrics. 1994;7(1):9-10.
23 Brewster DR. Management of chronic suppurative otitis media. Med J Aust. Jan. 19. 2004;180(2):91-2. author reply 2–3. [pmid: 14768072].
24 Broniatowski M, Katz RL. Causes and management of serous otitis media: current concepts. Ear Nose Throat J. Nov. 1981;60(11):511-8. [pmid: 6174284].
25 Brook I. Microbiology and management of chronic suppurative otitis media in children. J Trop Pediatr. Aug. 2003;49(4):196-9. [pmid: 12929878].
26 Brown A. Prevnar(TM): a pneumococcal conjugate vaccine for infants and young children (Structured abstract). Ottawa. Canadian Coordinating Office for Health Technology Assessment/Office Canadien de Coordination de l'Evaluation des Technologies de la Sante (CCOHTA). 2001:4.
27 Butler CC, van Der Voort JH. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2000;(4):CD001935. [pmid: 11034736].
28 Butler CC, van Der Voort JH. Steroids for otitis media with effusion: a systematic review. Arch Pediatr Adolesc Med. Jun. 2001;155(6):641-7. [pmid: 11386950].
29 Calandra LM. Otitis media with effusion. Outlining strategies and controversies. Adv Nurse Pract. Feb. 1998;6(2):67-70. [pmid: 9555285].
30 Campbell RG, Birman CS, Morgan L. Management of otitis media with effusion in children with primary ciliary dyskinesia: a literature review. Int J Pediatr Otorhinolaryngol. Dec. 2009;73(12):1630-8. [pmid: 19796826].
31 Cantekin EI. Antibiotics for secretory otitis media. Arch Otolaryngol Head Neck Surg. May. 1990;116(5):626-9. [pmid: 2183828].
32 Carlson L, Scudder L. Controversies in the management of pediatric otitis media. Are more definitive answers on the horizon?. Adv Nurse Pract. Feb. 2004;12(2):73-7. [pmid: 14986495].
33 Chaffee JR, St Anna L, Grover F Jr. Clinical inquiries. Are nasal steroid sprays effective for otitis media with effusion?. J Fam Pract. Aug. 2003;52(8):647-9. [pmid: 12899825].
34 Chandler JR. Middle ear infections. Current Opinion in Infectious Diseases. 1990;3(4):538-41.
35 Chmielik M, Brozek-Madry E, Debska M. Surgical treatment of secretory otitis media in children. New Medicine. 2006;9(3):68-70.
36 Coates H. Preventing and treating grommet tube otorrhoea. Medicine Today. 2002;3(10):77-9.
37 Cohen JI, Meyerhoff WL. Tympanostomy tube therapy for otitis media. Ear Hear. Mar–Apr. 1982;3(2):96-100. [pmid: 7042423].
38 Corwin MJ, Weiner LB, Daniels DA. Effects of oral antibiotics on the outcome of serous otitis media. Pediatr Res. 1982:238a. [pmid: 6278393].
39 Dagan R. Appropriate treatment of acute otitis media in the era of antibiotic resistance. Paediatr Drugs. Jun. 29. Suppl 1. 2010;12:3-9. [pmid: 20590168].
40 de Castro FJ, Jackson PL, Reed KD. Efficacy of oral leukotriene together with inhaled steroid in serous otitis media. Pediatr Res. 2001:14a. [pmid: 11420413].
41 Deitmer T. Topical and systemic treatment for chronic suppurative otitis media. Ear Nose Throat J. Aug. 2002;81(8 Suppl 1):16-7. [pmid: 12199182].
42 DeRosa J, Grundfast KM. Surgical management of otitis media. Pediatr Ann. Dec. 2002;31(12):814-20. [pmid: 12503439].
43 Donaldson JA. Surgical management of otitis media (recurrent and nonsuppurative). J Allergy Clin Immunol. May. 1988;81(5 Pt 2):1020-4. [pmid: 3286727].
44 Eliopoulos P, Balatsouras D, Sterpi P, et al. Improvement of otitis media with effusion after treatment of asthma by leukotriene antagonists in children with co-existing disease. Int J Pediatr Otorhinolaryngol. 2004:651.
45 Faden H, Duffy L, Boeve M. Otitis media: back to basics. Pediatr Infect Dis J. Dec. 1998;17(12):1105-12. quiz 12–3. [pmid: 9877357].
46 Feldman W. Early surgery was better than watchful waiting for language development in children with persistent otitis media with effusion. Evidence-Based Medicine. 1999;4(5):137.
47 Fireman P. Allergy induced eustachian tube and middle ear pathophysiology. N Engl Reg Allergy Proc. May–Jun. 1986;7(3):246-52. [pmid: 3302659].
48 French L. Are naturopathic herbal ear drops effective for ear pain in children?. Evidence-Based Practice. 2003;6(8):2-3. 2p. Language: English. Entry Date: 20040109. Revision Date: 20090814. Publication Type: journal article.
49 Gadre AK. Otitis media with effusion in a patient who had previously undergone a stapedectomy. Ear, Nose and Throat Journal. 2005;84(8):464.
50 Gannon M. Weight: an objective marker of gain after adenoidectomy in OME. [Abstract]. Autumn Meeting of the Otolaryngological Research Society (ORS). 24th September 2004. Institute of Laryngology and Otology. London, UK. Clinical Otolaryngology. 2005:579.
51 Gannon M, Dixon S, MRCMOMSG. Treatment needs in OME and long-term effectiveness of adenoidectomy: evidence from healthcare utilization around a randomized controlled trial. 8th International Symposium on Recent Advances in Otitis Media. Fort Lauderdale, FL, USA. 3–7 June, 2003. 2003:153. Abstract No. B32.
52 Garcia P, Gates GA, Schechtman KB. Does topical antibiotic prophylaxis reduce post-tympanostomy tube otorrhea? (Structured abstract). Ann Otol Rhinol Laryngol. 1994:54-8. [pmid: 8291860].
53 Gasper K, St Anna L, Montgomery L. Clinical inquiries. Are antibiotics effective for otitis media with effusion?. J Fam Pract. Apr. 2003;52(4):321-3. [pmid: 12681093].
54 Gates GA. Adenoidectomy for otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. May. 1994;163:54-8. [pmid: 8179272].
55 Giebink GS. Treatment of persistent otitis media. Pediatr Infect Dis J. Oct. 1995;14(10):922-3. [pmid: 8584335].
56 Gould JM, Matz PS. Otitis media. Pediatr Rev. Mar. 2010;31(3):102-16. [pmid: 20194902].
57 Grievink EH, Peters SA, van Bon WH, et al. The effects of early bilateral otitis media with effusion on language ability: a prospective cohort study. J Speech Hear Res. Oct. 1993;36(5):1004-12. [pmid: 8246466].
58 Grundfast KM. A review of the efficacy of systemically administered decongestants in the prevention and treatment of otitis media. Otolaryngol Head Neck Surg. May–Jun. 1981;89(3 Pt 1):432-9. [pmid: 6115352].
59 Haggard M. Applying trial results to a clinical policy: evidence-based indicators for two treatments permit consistency of intervention criteria within a discipline MRC Multi-Centre Otitis Media Study Group. [abstract]. 9th Annual Cochrane Colloquium. 2001 Oct 9–13. Lyon, France. 2001.
60 Haggard M. Evidence for high cost-effectiveness of 'adjuvant' adenoidectomy in OME in children over 3.5 years. Int J Pediatr Otorhinolaryngol. 2004:726.
61 Haggard M, Gannon M. A rational strategy for the treatment of glue ear. Practitioner. Feb. 9. 2000;244(1607):106-11. [pmid: 10892043].
62 Haggard M, Nicholls E, White I, et al. New adjusted analysis shows hearing level is an indicator for grommets. [Abstract]. Autumn Meeting of the Otolaryngological Research Society (ORS). 24th September 2004. Institute of Laryngology and Otology. London, UK. Clinical Otolaryngology. 2005:579.
63 Haggard M, Smith S, Spencer H, et al. Aspects of OME impact beyond hearing levels are important; evidence from dynamic modelling of changes. Associaton for Research in Otolaryngology. 1998.
64 Haggard MP. Developmental sequelae of OME in behaviour, and their remedial treatment by ventilation tubes in 3 and a half 7 year-olds - The UK randomised trial. 4th Extraordinary International Symposium on Recent Advances in Otitis Media. Sendai, Japan. 16–20 April, 2001. 2001:53. Abstract No. 10.
65 Hausdorff WP, Hoet B, Schuerman L. Do pneumococcal conjugate vaccines provide any cross-protection against serotype 19A?. BMC Pediatr. 2010;10:4. [pmid: 20122261].
66 Hayden FG. Influenza virus and rhinovirus-related otitis media: potential for antiviral intervention. Vaccine. Dec. 8. Suppl 1. 2000;19:S66-70. [pmid: 11163466].
67 Hayes, Inc. Antibiotic treatment for otitis media in children (Structured abstract). Lansdale, PA. HAYES, Inc. 2005.
68 Hellstrom S, Axelsson S, Bengtsson Bostrom K, et al. Tympanostomy tube insertion for otitis media in children (Structured abstract). Stockholm. Swedish Council on Technology Assessment in Health Care (SBU): Swedish Council on Technology Assessment in Health Care (SBU). 2008:1.
69 Hemmer S, Satre T. Does early insertion of tympanostomy tubes improve developmental outcomes of children with chronic middle ear effusion?. Evidence-Based Practice. 2010;13(5):8. Language: English. Entry Date: 20100618. Revision Date: 20100618. Publication Type: journal article.
70 Hendley JO. Clinical practice. Otitis media. N Engl J Med. Oct. 10. 2002;347(15):1169-74. [pmid: 12374878].
71 Higson J, Haggard MP, Adams D, et al. Speech-in-noise as an outcome measure and indication for ventilation tubes (VTs) in OME. 8th International Symposium on Recent Advances in Otitis Media. Fort Lauderdale, FL, USA. 3–7 June, 2003. 2003:327. Abstract No. P74.
72 Ho WK, Wei W, Kwong DSJ. Hearing gain after grommet insertion for middle ear infusion (OME) in patients with nasopharyngeal carcinoma (NPC) - A randomised study. [abstract no: 113] V. 5th International Conference on Head and Neck Cancer. San Fransico, California. 29 Jul –2 Aug 2000. 2000:95.
73 Hoppe MW. Ear infections and their treatment in pediatrics. Drug Topics. 1998;142(16):93-102.
74 Husain N, Huang A, Ramos O. Otitis media: Current diagnosis and treatment. International Pediatrics. 2009;24(4):174-82.
75 Jacobs MR. Increasing antibiotic resistance among otitis media pathogens and their susceptibility to oral agents based on pharmacodynamic parameters. Pediatr Infect Dis J. May. 2000;19(5 Suppl):S47-55. discussion S-6. [pmid: 10821472].
76 Jacobs MR. Prevention of otitis media: role of pneumococcal conjugate vaccines in reducing incidence and antibiotic resistance. J Pediatr. Aug. 2002;141(2):287-93. [pmid: 12183732].
77 Klein JO. Nonimmune strategies for prevention of otitis media. Pediatr Infect Dis J. May. 2000;19(5 Suppl):S89-92. [pmid: 10821477].
78 Klein JO. Changes in management of otitis media: 2003 and beyond. Pediatr Ann. Dec. 2002;31(12):824-6. 9. [pmid: 12503440].
79 Kokko E. Chronic secretory otitis media in children. A clinical study. Acta Otolaryngol Suppl. 1974;327:1-44. [pmid: 4534033].
80 Kokko E, Palva T. Clinical results and complications of tympanostomy. Ann Otol Rhinol Laryngol. Mar–Apr. 1976;85(2 Suppl 25 Pt 2):277-9. [pmid: 1267359].
81 Koopman JP, Blom H, Hoeve H, et al. Laser myringotomy versus ventilation tubes in children with chronic otitis media with effusion: a randomized trial for efficacy and outcome prediction. 8th International Symposium on Recent Advances in Otitis Media. 2003:136.
82 Koopman JP, Reuchlin AE, Kummer EE, et al. The efficacy of laser assisted myringotomy versus ventilation tubes in children with chronic otitis media. Clinical Otolaryngology and Allied Sciences. 2004:434.
83 Kouwen H, van Balen FA, Dejonckere PH. Functional tubal therapy for persistent otitis media with effusion in children: myth or evidence?. Int J Pediatr Otorhinolaryngol. Jul. 2005;69(7):943-51. [pmid: 15911013].
84 Kripke C. Decongestants and antihistamines do not relieve symptoms of otitis media with effusion. Am Fam Physician. Apr. 1. 2007;75(7):1001. [pmid: 17427613].
85 Kumar VV, Gaughan J, Isaacson G, et al. Oxymetazoline is equivalent to ciprofloxacin in preventing postoperative otorrhea or tympanostomy tube obstruction. Laryngoscope. 2005;115(2):363-5. [pmid: 15689767].
86 Leach A, Morris P. Pneumococcal resistance of long-term antibiotics for prevention of otitis media: a randomized placebo controlled trial ina high-risk population. 8th International Symposium on Recent Advances in Otitis Media. Fort Lauderdale, FL, USA. 3–7 June, 2003. 2003:250. Abstract No. P6.
87 Leach A, Morris PMJ. Clinical outcomes of long-term antibiotics for prevention of acute otitis media without perforation (AOM/woP), AOM with perforation (AOM/wiP) and chronic suppurative otitis media (CSOM): a randomized placebo controlled trial in a high risk population. 8th International Symposium on Recent Advances in Otitis Media. 2003 June 3–7. Fort Lauderdale, FL. 2003.
88 Leighton JM. Does manual therapy such as chiropractic offer an effective treatment modality for chronic otitis media?. Clinical Chiropractic. 2009;12(4):144-8. Language: English. Entry Date: 20100528. Revision Date: 20100528. Publication Type: journal article.
89 Lous J, Burton MJ, Felding JU, et al. Grommets (ventilation tubes) for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2005;(1):CD001801. [pmid: 15674886].
90 Marchant CD, Shurin PA. Therapy of otitis media. Pediatr Clin North Am. Apr. 1983;30(2):281-96. [pmid: 6190123].
91 Margas K, Mourtzouhos C, Assimakopoulos A, et al. Treatment of otitis media with effusion (OME): antibiotics vs. antihistamines–our experience. Int J Pediatr Otorhinolaryngol. 2004:644.
92 Markou K, Vlachtsis K, Kyriafinis G, et al. Long-term results of adenoidectomy and ventilation tube insertion in the surgical treatment of chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. 2004:684.
93 Maw AR. The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial. [letter]. Clinical Otolaryngology and Allied Sciences. 1987:155-6. [pmid: 3555892].
94 Maw R, Wilks J, Harvey I, et al. Randomised controlled trial of early surgery versus watchful waiting for glue ear: the effect of langauge development in pre-school children. 10th British Academic Conference in Otolaryngology (BACO). 4–9 July 1999. Cambridge, UK. Journal of Laryngology. 1999:40.
95 Moller P. Selective use of ventilating tubes in the treatment of secretory otitis media and retractions of the ear drum. Acta Otolaryngol (Stockh). 1982;93(s386):158-60.
96 Morris P, Mathews J. Long-term antibiotics for the prevention of otitis media in aboriginal children: a randomised controlled trial. J Paediatr Child Health. 2003:A6.
97 Morris PS, Leach AJ. Acute and Chronic Otitis Media. Pediatr Clin North Am. 2009;56(6):1383-99. [pmid: 19962027].
98 National Collaborating Centre for Women’s and Children’s Health. Surgical Management of Otitis Media With Effusion in Children. NICE Clinical Guideline 60. London. National Institute for Health and Clinical Excellence. 2008.
99 Paradise JL. Generalizability of randomized trial results: tympanostomy-tube insertion and tonsillectomy. Otolaryngol Head Neck Surg. Mar. 2009;140(3):439-40. author reply 40–1. [pmid: 19248964].
100 Paradise JL, Colborn DK, Bernard BS, et al. Comparison of the early results of tympanostomy tube placement and of nonsurgical management in infants with persistent otitis media. Recent Advances in Otitis Media. 6th International Symposium on Recent Advances in Otitis Media. Jun 04–08, 1995. Ft Lauderdale, Florida. 1996:201.
101 Paradise JL, Feldman HM, Campbell TF, et al. No difference existed in development outcomes at 3 years of age between early or delayed tympanostomy for otitis media. ACP J Club. 2001:108.
102 Parrella A, Mundy L, Hiller J. EarPopper (TM) for the treatment of otitis media with effusion in children. Horizon Scanning Prioritising Summary - Volume 11 (Structured abstract). Adelaide. Adelaide Health Technology Assessment (AHTA) on behalf of National Horizon Scanning Unit (HealthPACT and MSAC): Adelaide Health Technology Assessment (AHTA) on behalf of National Horizon Scanning Unit (HealthPACT and MSAC). 2005.
103 Pestalozza G. Otitis media in newborn infants. Int J Pediatr Otorhinolaryngol. Dec. 1984;8(2):109-24. [pmid: 6526580].
104 Plontke Stefan K, Meisner C, Caye-Thomasen P, et al. Intratympanic glucocorticoids for sudden sensorineural hearing loss. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
105 Reviews NHSCf Dissemination. The treatment of persistent glue ear in children (Structured abstract). York. Centre for Reviews and Dissemination (CRD): Centre for Reviews and Dissemination (CRD). 1992:12.
106 Robertson J. Developmental outcomes did not differ for early or delayed tympanostomy tube insertion in young children with otitis media. Evidence-Based Nursing. 2001:108.
107 Rosenfeld RM. Surgical prevention of otitis media. Vaccine. Dec. 8. Suppl 1. 2000;19:S134-9. [pmid: 11163477].
108 Rosenfeld RM. Antibiotic use for otitis media: oral, topical, or none?. Pediatr Ann. Dec. 2004;33(12):833-42. [pmid: 15615310].
109 Rovers MM, Black N, Browning GG, et al. Grommets in otitis media with effusion: an individual patient data meta-analysis. Arch Dis Child. May. 2005;90(5):480-5. [pmid: 15851429].
110 Rovers MM, Zielhuis K, Ingels H, et al. The effect of early screening and treatment with ventilation tubes in infants with persistent otitis media with effusion. Clinical Otolaryngology and Allied Sciences. 2003:158.
111 Scotland NHSQI. The clinical and cost effectiveness of surgical insertion of grommets for otitis media with effusion (glue ear) in children (Structured abstract). Glasgow. NHS Quality Improvement Scotland (NHS QIS): NHS Quality Improvement Scotland (NHS QIS). 2008:4.
112 Seehusen DA, Macdonnell J. Steroids for the treatment of otitis media with effusion in children. Am Fam Physician. 2012;85(3):235-6. [pmid: 22335261].
113 Shiao AS, Lin SH. CO2 laser myringotomy in children with otitis media. Int J Pediatr Otorhinolaryngol. 2004:688.
114 Simpson KL, Markham A. Ofloxacin otic solution: a review of its use in the management of ear infections. Drugs. Sep. 1999;58(3):509-31. [pmid: 10493278].
115 Smyth GD, Hall S. Aetiology and treatment of persistent middle-ear effusion. J Laryngol Otol. Dec. 1983;97(12):1085-9. [pmid: 6358386].
116 Spurling GK, Del Mar CB, Dooley L, et al. Delayed antibiotics for symptoms and complications of respiratory infections. Cochrane Database Syst Rev. 2004;(4):CD004417. [pmid: 15495108].
117 Stephens MB. Does delaying placement of tympanostomy tubes have an adverse effect on developmental outcomes in children with persistent middle ear effusions?. J Fam Pract. Aug. 2001;50(8):651. [pmid: 11509152].
118 Stool S, Carlson LH, Johnson CE. Otitis media: diagnosis, management, and judicious use of antibiotics. Curr Allergy Asthma Rep. Jul. 2002;2(4):297-303. [pmid: 12044264].
119 Thomson J, Sederberg-Olsen J, Balle V, et al. Antibiotic treatment of children with secretory otitis media. Amoxicillin-clavulanate potassium is superior to penicillin v. A double-blind, randomized study. Otorhinolaryngology Head and Neck Surgery, 16th World Congress. Sydney, Australia. 1997. 1997:1049-52.
120 Unlu Y, Haberal Y, Emyr H, et al. The comparison of different antibiotics and the effect of mucolitics in treatment of otitis media with effusion. XVIII IFOS World Congress. Rome, Italy. 25–30 June, 2005. 2005.
121 van de Heyning PH, Pattyn SR, Valcke HD, et al. The use of fluoroquinolones in chronic otitis suppurativa. Pharm Weekbl Sci. Dec. 11. Suppl. 1987;9:S87-9. [pmid: 3325935].
122 Vlastarakos PV, Nikolopoulos TP, Korres S, et al. Grommets in otitis media with effusion: the most frequent operation in children. But is it associated with significant complications?. Eur J Pediatr. May. 2007;166(5):385-91. [pmid: 17225951].
123 Westerberg BD, Morzaria S, Kozak FK, et al. Medical management of middle ear disease in children less than 2 years of age with sensorineural hearing loss. J Otolaryngol. Aug. Suppl 2. 2005;34:S64-9. [pmid: 16076419].
124 Williamson I. Otitis media with effusion. Clin Evid. Jun. 2002;(7):469-76. [pmid: 12230672].
125 Williamson I. Otitis media with effusion in children. Clinical Evidence. 2011. [pii: 0502]. [pmid: 21477396].
126 Witmer A, Wells AM, Seymour RJ. A comparison of the effectiveness of pharmacologic treatment of otitis media with effusion in children: integrative and meta-analysis (Structured abstract). Online Journal of Knowledge Synthesis for Nursing. 1998.
127 Zaphiris A, Mills MV, Jewell NP, et al. Osteopathic manipulative treatment and otitis media: does improving somatic dysfunction improve clinical outcomes?. JAOA: Journal of the American Osteopathic Association. 2004;104(1):11. Language: English. Entry Date: 20040813. Revision Date: 20091218. Publication Type: journal article.
128 Ackerman SJ, Duff SB, Dennehy PH, et al. Economic impact of an infection control education program in a specialized preschool setting (Structured abstract). Pediatrics. 2001:E102. [pmid: 11731629].
129 Ahn JH, Kang WS, Kim JH, et al. Clinical manifestation and risk factors of children with cleft palate receiving repeated ventilating tube insertions for treatment of recurrent otitis media with effusion. Acta Otolaryngol. 2012;132(7):702-7. [pmid: 22668076].
130 Alabi BS, Bolaji BO, Segun-Busari S, et al. Outcome of grommet tube insertions among adult Nigerians with serous otitis media. Ann Afr Med. Oct–Dec. 2009;8(4):281-2. [pmid: 20139554].
131 Andreasson L, Bylander A, Ivarsson A, et al. Treatment with sulfur hexafluoride in children with serous otitis media. An alternative to tubulation. Arch Otolaryngol. Jun. 1983;109(6):358-9. [pmid: 6682653].
132 Arnold DJ, Bressler KL. Permeability of tympanotomy tubes to ototopical preparations. Otolaryngol Head Neck Surg. Jul. 1999;121(1):35-7. [pmid: 10388874].
133 Asiri SM, Abu-Bakr YA, Al-Enazi F. Paediatric ENT day surgery: is it a safe practice?. Ambulatory Surgery. 2006;12(4):147-9. Language: English. Entry Date: 20060929. Revision Date: 20091218. Publication Type: journal article.
134 Barenkamp SJ, Kurono Y, Ogra PL, et al. Recent advances in otitis media. 5. Microbiology and immunology. Ann Otol Rhinol Laryngol Suppl. Jan. 2005;194:60-85. [pmid: 15700937].
135 Becker SP, Roberts N, Coglianese D. Endoscopic adenoidectomy for relief of serous otitis media. Laryngoscope. Dec. 1992;102(12 Pt 1):1379-84. [pmid: 1453847].
136 Bellavite P. Homeopathic treatment of otitis media: a literature review. Alternative & Complementary Therapies. 2008;14(5):246-7. Language: English. Entry Date: 20090102. Revision Date: 20090102. Publication Type: journal article.
137 Berman S, Roark R, Luckey D. Theoretical cost effectiveness of management options for children with persisting middle ear effusions. Pediatrics. Mar. 1994;93(3):353-63. [pmid: 8115191].
138 Bhattacharyya N. Ambulatory pediatric otolaryngologic procedures in the United States: characteristics and perioperative safety. Laryngoscope. Apr. 2010;120(4):821-5. [pmid: 20213790].
139 Boudewyns A, Declau F, Van den Ende J, et al. Otitis media with effusion: an underestimated cause of hearing loss in infants. Otol Neurotol. Jul. 2011;32(5):799-804. [pmid: 21593700].
140 Choi HG, Park KH, Park SN, et al. The appropriate medical management of methicillin-resistant Staphylococcus aureus in chronic suppurative otitis media. Acta Otolaryngol. 2010;130(1):42-6. [pmid: 19424918].
141 Daly KA, Hunter LL, Lindgren BR, et al. Chronic otitis media with effusion sequelae in children treated with tubes. Arch Otolaryngol Head Neck Surg. May. 2003;129(5):517-22. [pmid: 12759263].
142 Deguine C, Pulec JL. Reaction from a long-term ventilating tube. Ear Nose Throat J. Nov. 2002;81(11):756. [pmid: 12472022].
143 Dornan B, Fligor B, Whittemore K, et al. Pediatric hearing assessment by auditory brainstem response in the operating room. Int J Pediatr Otorhinolaryngol. 2011;75(7):935-8. [pmid: 21571378].
144 Emery M, Weber PC. Hearing loss due to myringotomy and tube placement and the role of preoperative audiograms. Arch Otolaryngol Head Neck Surg. Apr. 1998;124(4):421-4. [pmid: 9559690].
145 Estrem SA, Batra PS. Conductive hearing loss associated with pressure equalization tubes. Otolaryngol Head Neck Surg. Mar. 2000;122(3):349-51. [pmid: 10699808].
146 Fernandez-Blasini N. Use and abuse of ventilation tubes. Am J Otol. Mar. 1985;6(2):142-5. [pmid: 4039110].
147 Ford-Jones EL, Friedberg J, McGeer A, et al. Microbiologic findings and risk factors for antimicrobial resistance at myringotomy for tympanostomy tube placement--a prospective study of 601 children in Toronto. Int J Pediatr Otorhinolaryngol. Dec. 2. 2002;66(3):227-42. [pmid: 12443811].
148 Gates G. Cost effectiveness consideration in otitis media treatment. Otolaryngol Head Neck Surg. 1996;114:525-30. [pmid: 8643261].
149 Gunasekera H, Morris PS, McIntyre P, et al. Management of children with otitis media: a summary of evidence from recent systematic reviews. J Paediatr Child Health. Oct. 2009;45(10):554-62. quiz 62–3. [pmid: 19751382].
150 Heikkinen T, Saeed KA, McCormick DP, et al. A single intramuscular dose of ceftriaxone changes nasopharyngeal bacterial flora in children with acute otitis media. Acta Paediatr. Nov. 2000;89(11):1316-21. [pmid: 11106042].
151 Hong P, Smith N, Johnson LB, et al. A randomized double-blind controlled trial of phosphorylcholine-coated tympanostomy tube versus standard tympanostomy tube in children with recurrent acute and chronic otitis media. Laryngoscope. Jan. 2011;121(1):214-9. [pmid: 21072756].
152 Jehle D, Cottington E. Acoustic otoscopy in the diagnosis of otitis media. Ann Emerg Med. Apr. 1989;18(4):396-400. [pmid: 2650590].
153 Kalcioglu MT, Ozturan O, Durmaz R, et al. In vitro efficacy of the successive or staggered use of eardrops. Eur Arch Otorhinolaryngol. May. 2006;263(5):395-8. [pmid: 16328405].
154 Kanemaru S, Nakamura T, Yamashita M, et al. 5-Fluorouracil ointment for the treatment of otitis media with effusion. Laryngoscope. Feb. 2007;117(2):215-9. [pmid: 17277614].
155 Keyhani S, Kleinman LC, Rothschild M, et al. Clinical characteristics of New York City children who received tympanostomy tubes in 2002. Pediatrics. Jan. 2008;121(1):e24-33. [pmid: 18166541].
156 Kojima H, Sakurai Y, Rikitake M, et al. Cochlear implantation in patients with chronic otitis media. Auris Nasus Larynx. Aug. 2010;37(4):415-21. [pmid: 20189327].
157 Laina V, Pothier DD. Should we aspirate middle-ear effusions prior to insertion of ventilation tubes?. J Laryngol Otol. Oct. 2006;120(10):818-21. [pmid: 17038228].
158 Le CT, Lindgren BR. Duration of ventilating tubes: a test for comparing two clustered samples of censored data. Biometrics. Mar. 1996;52(1):328-34. [pmid: 8934600].
159 Lin YC, Wang WH, Weng HH. Predictors of surgical and hearing long-term results for inlay cartilage tympanoplasty. Arch Otolaryngol Head Neck Surg. Mar. 2011;137(3):215-9. [pmid: 21422303].
160 Liston TE. Management of otitis media. A review. Clin Pediatr (Phila). Oct. 1995;34(10):542-8. [pmid: 8591682].
161 Moore RA, Commins D, Bates G, et al. S-carboxymethylcysteine in the treatment of glue ear: quantitative systematic review. BMC Fam Pract. 2001;2:3. [pmid: 11580867].
162 Oberman JP, Derkay CS. Posttympanostomy Tube Otorrhea. American Journal of Otolaryngology - Head and Neck Medicine and Surgery. 2004;25(2):110-7.
163 O'Shea JS, Regan JB, Langenbrunner DJ, et al. Childhood otitis media with effusion: six-year follow-up. J Otolaryngol. Oct. 1986;15(5):303-5. [pmid: 3773046].
164 Perriello VA, Ford RF, McLean WC, et al. Otitis media: a review. Va Med. May. 1977;104(5):319-20. 25. 8. [pmid: 871068].
165 Postma DS, Poole MD, Wu SM, et al. The impact of day care on ventilation tube insertion. Int J Pediatr Otorhinolaryngol. Sep. 18. 1997;41(3):253-62. [pmid: 9350484].
166 Rosenfeld RM, Goldsmith AJ, Tetlus L, et al. Quality of life for children with otitis media. Arch Otolaryngol Head Neck Surg. Oct. 1997;123(10):1049-54. [pmid: 9339979].
167 Rosenfeld RM, Mandel EM, Bluestone CD. Systemic steroids for otitis media with effusion in children. Arch Otolaryngol Head Neck Surg. Sep. 1991;117(9):984-9. [pmid: 1832876].
168 Rovers M, Zielhuis G, Hartman M, et al. The effect of early screening and treatment with ventilation tubes in infants with persistent otitis media with effusion. ISTAHC Annual Meeting. 2000.
169 Saunders L. Chiropractic treatment of otitis media with effusion: a case report and literature review of the epidemiological risk factors that predispose towards the condition and that influence the outcome of chiropractic treatment. Clinical Chiropractic. 2004;7(4):168-73. Language: English. Entry Date: 20050902. Revision Date: 20060106. Publication Type: journal article.
170 Schilder AG. Assessment of complications of the condition and of the treatment of otitis media with effusion. Int J Pediatr Otorhinolaryngol. Oct. 5. Suppl 1. 1999;49:S247-51. [pmid: 10577815].
171 Zipfel TE, Wood WE, Street DF, et al. The effect of topical ciprofloxacin on postoperative otorrhea after tympanostomy tube insertion. Am J Otol. Jul. 1999;20(4):416-20. [pmid: 10431879].
172 van den Aardweg MT, Schilder AG, Herkert E, et al. Adenoidectomy for recurrent or chronic nasal symptoms in children. Cochrane Database Syst Rev. 2010;(1):CD008282. [pmid: 20091663].
173 Aizenberg SG. Patency of the eustachian tube in patients with chronic suppurative otitis media and its effect on the tympanoplasty outcome. Zh Ushn Nos Gorl Bolezn. Mar–Apr. 1967;27(2):30-4. [pmid: 5620663].
174 Andersen JB. Otitis media and antibiotics. Ugeskr Laeger. Aug. 12. 2002;164(33):3876-7. [pmid: 12216165].
175 Aref'eva NA, Stratieva OV, Salakhova GM, et al. Validation of therapeutical policy choice in exudative otitis media. Vestn Otorinolaringol. 1998;(2):24-7. [pmid: 9560978].
176 Arola M, Ruuskanen O, Puhakka H. Problems related to the treatment of otitis media. Duodecim. 1992;108(20):1761-6. [pmid: 1345270].
177 Balle V, Tos M. Tympanoplasty on the sole hearing ear. Ugeskr Laeger. Feb. 17. 1986;148(8):444-6. [pmid: 3961981].
178 Becker CG, Da Silva AL, Guimaraes RES, et al. Surgical treatment of otitis media with effusion: Ventilation tube versus topical application of mitomycin C. Revista Brasileira De Otorrinolaringologia. 2003:513-9.
179 Benito Jimenez J, Villafruela Sanz MA. Otorhinolaryngology course for pediatricians: Adenoid growths. Pathophysiology. Indications for treatment. Otitis media with effusion. Anales de Pediatria. 2003;58(1 MONO. 1):72-80.
180 Bogomil'skii MR, Garashchenko TI, Denisova OA. Assessment of the effectiveness of sinuforte used for the combined treatment of rhinosinusitis and exudative otitis media in children. Vestn Otorinolaringol. 2010;(4):74-7. [pmid: 21105351].
181 Burgos Sanchez A, Menaches Guardiola MI, Gras Albert JR, et al. Descriptive study of infectious ear disease in relation to summer. Acta Otorrinolaringol Esp. Jan–Feb. 2000;51(1):19-24. [pmid: 10799927].
182 Camaioni A, Bicciolo G, Croce A. Role of anaerobic bacteria in the etiopathogenesis of chronic purulent otitis media. Acta Otorhinolaryngol Ital. Jan–Feb. 1987;7(1):67-75. [pmid: 3618205].
183 Cannoni M, Bonfils P, Sednaoui P, et al. Cefotiam hexetil versus amoxicillin/clavulanic acid for the treatment of chronic otitis media in adults. <ORIGINAL> EFFICACITE ET TOLERANCE DU CEFOTIAM HEXETIL VERSUS AMOXICILLINE/ACIDE CLAVULANIQUE DANS LE TRAITEMENT DE L'OTITE MOYENNE CHRONIQUE DE L'ADULTE. Medecine Et Maladies Infectieuses. 1997:915-21.
184 Capella Bujosa G, Amador MT. Serous otitis media. An Otorrinolaringol Ibero Am. 1984;11(3):195-220. [pmid: 6205607].
185 Caye-Thomasen P, Thomsen JC. Surgical and local medical treatment of the inner ear. Ugeskr Laeger. 2004;166(8):701-2. [pmid: 15042819].
186 Chen XH, Wu X, Huang B. Relationship between the content of fibrinogen in middle ear effusion and the effect of treatment on secretory otitis media. Zhonghua Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. Aug. 2006;41(8):566-9. [pmid: 17039794].
187 Cherpillod J. Secretory otitis: a review. Rev Med Suisse Romande. Jul. 1988;108(7):617-23. [pmid: 3045940].
188 Cherpillod J. Some current problems in pediatric otorhinolaryngology. Rev Med Suisse Romande. Mar. 2000;120(3):203-6. [pmid: 10815449].
189 Cotulbea S, Marin I, Cev P, et al. Correlation between the otic and rhinopharyngeal microbial flora in chronic suppurative otitis media in adults. Rev Chir Oncol Radiol O R L Oftalmol Stomatol Otorinolaringol. Jul–Sep. 1984;29(3):199-204. [pmid: 6238366].
190 De Gandt JB, Hiernaux R. Incidence of surgical treatment in serous otitis. Acta Otorhinolaryngol Belg. 1983;37(1):57-66. [pmid: 6684383].
191 Dellamonica P, Choutet P, Lejeune JM, et al. Efficacy and safety of cefotiam hexetil in the treatment of chronic otitis media. A comparative double blind randomized study versus cefuroxime axetil. Medecine Et Maladies Infectieuses. 1995:733-9.
192 Devars F, Traissac L. Seromucous otitis. Treatment and long-term development. Rev Laryngol Otol Rhinol (Bord). 1993;114(3):221-4. [pmid: 8191069].
193 Dmitriev NS, Mileshina NA. Surgical treatment of patients with exudative otitis media. Vestn Otorinolaringol. 2003;(6):49-51. [pmid: 14671582].
194 Enin EP, Morenko VM. Polysorb as an immobilizing matrix for the drugs used for the local therapy of otitis media. Vestn Otorinolaringol. Jul–Aug. 1993;4:41-2. [pmid: 8036759].
195 Fiebach A, Matschke RG. Duration and complications following grommet insertion in childhood. HNO. Feb. 1987;35(2):61-6. [pmid: 3570884].
196 Fuchs M, Arnold W. Indications for the insertion of ventilating tubes in the mucotympanum of the child. Laryngol Rhinol Otol (Stuttg). Jan. 1986;65(1):21-3. [pmid: 3951290].
197 Gimsing S. Tympanometry and myringotomy findings in secretory otitis media. Ugeskr Laeger. Dec. 5. 1983;145(49):3816-8. [pmid: 6686728].
198 Gordts F, Clement PA, Derde MP. Lens drain versus Donaldson drain: intermediate results of a prospective comparative study of a new versus a classical ventilation tube. Acta Otorhinolaryngol Belg. 1989;43(1):59-65. [pmid: 2801097].
199 Grasl M, Welleschik B. Functional results of tympanum drainage in chronic seromuco-tympanum--Clinical course up to 2 years following the operation. Laryngol Rhinol Otol (Stuttg). Sep. 1983;62(9):394-401. [pmid: 6633100].
200 Grote JJ, Jansen JB. Serous otitis media viewed from 2 angles. Ned Tijdschr Geneeskd. Aug. 6. 1977;121(32):1262-5. [pmid: 895911].
201 Gudziol V, Mann WJ. Otological findings in adults with isolated cleft palate or cleft lip, jaw, and palate. Mund Kiefer Gesichtschir. Nov. 2004;8(6):356-60. [pmid: 15583925].
202 Gurov AV, Guseva AL. Microbiological characteristics of otitis media purulenta chronica: effects on the disease course. Vestn Otorinolaringol. 2007;(2):7-10. [pmid: 17828078].
203 Harigai S. Longitudinal studies in hearing-impaired children with Down's syndrome. Nippon Jibiinkoka Gakkai Kaiho. Dec. 1994;97(12):2208-18. [pmid: 7861292].
204 Hattori Y. Otitis media with effusion in children. Nippon Ika Daigaku Zasshi. Apr. 1994;61(2):160-3. [pmid: 8195326].
205 Haugeto OK, Elverland HH, Schroder KE, et al. Chronic secretory otitis. Tidsskr Nor Laegeforen. Oct. 20. 1980;100(29):1713-5. [pmid: 7466755].
206 Haugeto OK, Schroder KE, Mair IW. Treatment of secretory otitis with oral sympathomimetics. Tidsskr Nor Laegeforen. Mar. 10. 1982;102(7):426-8. [pmid: 6130642].
207 He Y, Xu H, Zhen Q, et al. The influence of palatoplasty and tympanotomy on middle ear function in cleft palate patients. Hua Xi Kou Qiang Yi Xue Za Zhi. Aug. 2001;19(4):243-5. [pmid: 12539732].
208 Hellstrom S, Pettersson A. Tympanostomy tube treatment in otitis media. A systematic literature review. SBU summary and conclusions. Lakartidningen. Jul 23–Aug 5. 2008;105(30–31):2104-6. [pmid: 18751449].
209 Herranz Jordan B, Sanchez Casado ML, Carrasco Claver F. Otitis media in pediatric primary care. Aten Primaria. Jun. 30. 1993;12(2):102-3. 5. 8. [pmid: 8329539].
210 Heumann H. Chronic suppurative otitis media in the child. Treatment and results. Laryngol Rhinol Otol (Stuttg). Jan. 1987;66(1):19-20. [pmid: 3561121].
211 Hormann K, Roehrs M. Middle-ear findings in young cleft lip and palate children. Comparison of two treatment clinics. Dtsch Z Mund Kiefer Gesichtschir. Mar–Apr. 1991;15(2):149-52. [pmid: 1816937].
212 Hozawa T. Evidence-based macrolide therapy for children with serous otitis media. Jpn J Antibiot. Dec. Suppl C. 2001;54:30-2. [pmid: 12575413].
213 Huang Z, Luo R, Wen R, et al. Auditory brainstem response in children before and after myringotomy with grommet insertion. Lin Chuang Er Bi Yan Hou Ke Za Zhi. Aug. 2006;20(16):752-4. [pmid: 17058924].
214 Huttenbrink KB. Surgical treatment of chronic otitis media. II: Cholesteatoma removal, open and closed techniques. HNO. Oct. 1994;42(10):648-57. [pmid: 8002373].
215 Iarlykov SA, Poliakova SD, Zemskov AM. Correction of immunologic disorders in patients with chronic suppurative otitis media. Vestn Otorinolaringol. Jan–Feb. 1995;(1):9-11. [pmid: 7725591].
216 Iino Y, Ishitoya J, Ikeda M, et al. Factors on delayed recovery of otitis media with effusion in children--clinical and bacteriological study. Nippon Jibiinkoka Gakkai Kaiho. Aug. 1989;92(8):1183-91. [pmid: 2685215].
217 Irla M. Complications of otitis media in children. Kinderkrankenschwester. Jan. 2007;26(1):3-6. [pmid: 17294782].
218 Jezewska E, Kukwa A, Jablonska J, et al. The efficacy of tympanopunction in children with OMS. Otolaryngol Pol. 2008;62(3):288-90. [pmid: 18652151].
219 Jiang Z, Liu W, Zhao C, et al. Adjuvant treatment of anisodamine to acute serous otitis media. Lin Chuang Er Bi Yan Hou Ke Za Zhi. Jul. 2004;18(7):406-7. [pmid: 15499981].
220 Jimenez Antolin JA, Lasso Luis O, Munoz Plato E, et al. Myringotomy and transtympanic ventilation tubes in secretory otitis media. A study of 108 children. Acta Otorrinolaringol Esp. Nov–Dec. 1994;45(6):415-9. [pmid: 7873230].
221 Juola E. Drug prophylaxis of pediatric otitis media. Duodecim. 1989;105(20):1640-3. [pmid: 2680455].
222 Karlidag T, Kaygusuz I, Gok U, et al. The efficacy of combining antibiotic treatment with topical intranasal steroid administration in the treatment of chronic otitis media with effusion. Kulak Burun Bogaz Ihtis Derg. Jul–Aug. 2002;9(4):257-62. [pmid: 12422079].
223 Klonowski S, Semczuk B, Burzynska A. Evaluation of the results of conservative and surgical treatment of otitis media in children. Pol Tyg Lek. Jan. 23. 1967;22(4):135-7. [pmid: 6042958].
224 Kochen MM. Antibiotics in otitis media?. Z Arztl Fortbild Qualitatssich. Oct. 2004;98(7):566. [pmid: 15595596].
225 Kumral TL, Veyseller B, Ulusan M, et al. Value of otoacoustic emission tests in the diagnosis and follow-up of the otitis media with effusion. Kulak Burun Bogaz Ihtis Derg. May–Jun. 2010;20(3):123-8. [pmid: 20465537].
226 LebedevIu A, Shakhov V. Criteria of the evaluation of tubal function in patients with secretory otitis media. Vestn Otorinolaringol. 1997;(3):30-4. [pmid: 9229916].
227 Leunig A, Mees K. Middle ear ventilation with the Otovent latex membrane system. Laryngorhinootologie. Jun. 1995;74(6):352-4. [pmid: 7662078].
228 Leunig A, Mees K. Autoinflation of the middle ear with otovent(TM). Laryngorhinootologie. 1995:352-4. [pmid: 7662078].
229 Li K, Zhao N, Sun Y. Clinical therapeutic effects of staging tympanoplasty. Lin Chung Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. May. 2007;21(10):441-3. [pmid: 17650811].
230 Li Y, Chen J, Tao Z. Clinical analysis of sensorineural hearing loss associated with otitis media with effusion in children. Lin Chung Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. Feb. 2009;23(4):154-6. [pmid: 19452716].
231 Liu L, Sun YG, Ma L, et al. Effect of ventilation tube insertion on otitis media with effusion in cleft palate children. Zhonghua er bi yan hou ke za zhi. 2004:216-8. [pmid: 15283281].
232 Long X, Feng X, Zhang T, et al. Mastoidectomy and ventilation tube placement for refractory secretory otitis media. Lin Chung Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. Jul. 2011;25(13):590-2. [pmid: 21949989].
233 Lorente J, Sabater F, Maristany M, et al. Multicenter study comparing the efficacy and tolerance of topical ciprofloxacin (0.3%) versus topical gentamicin (0.3%) in the treatment of simple, non-cholesteatomaous chronic otitis media in the suppurative phase. An Otorrinolaringol Ibero Am. 1995;22(5):521-33. [pmid: 7485860].
234 Lous J, Trankjaer CR, Thomsen J. Grommets (ventilation tubes) for recurrent acute otitis media in children--assessment of a Cochrane review. Ugeskr Laeger. Sep. 13. 2010;172(37):2526-30. [pmid: 20836962].
235 Marchant H, Bisschop P. Value of laser CO2 myringotomy in the treatment of seromucous otitis. Ann Otolaryngol Chir Cervicofac. Dec. 1998;115(6):347-51. [pmid: 9922831].
236 Mei LY, Feng Y, Liu HB, et al. Surgery of ventilation tube insertion in the middle ear and the external auditory canal for chronic secretory otitis media in children. Zhongguo Dang Dai Er Ke Za Zhi. Apr. 2008;10(2):155-7. [pmid: 18433535].
237 Michel O. External otitis and otitis media: diagnostics and treatment. MMW Fortschr Med. Aug. 12. 2010;152(31–33):38-41. quiz 2. [pmid: 20828067].
238 Mizuyoshi Y. Follow-up study of secretory otitis media after adenoidectomy and tonsillectomy. Nippon Jibiinkoka Gakkai Kaiho. May. 1991;94(5):649-56. [pmid: 1880637].
239 Ortega del Alamo P, Rivera RT, Sanz FR. The effect of AM3 in the resolution of otitis media with effusion (OME) in paediatric patients. Acta Otorrinolaringol Esp. 2005:1-5. [pmid: 15747716].
240 Peng BG, Miao XT, Wang X, et al. Experience in overlay tympanoplasty. Zhonghua Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. May. 2009;44(5):369-72. [pmid: 19567043].
241 Podoshin L, Brodzki A, Fradis M, et al. Local treatment of purulent chronic otitis media with ciprofloxacin. Harefuah. Jan. 1. 1998;134(1):32-6. 78. [pmid: 9517277].
242 Pospiech L, Rak J, Jaworska M, et al. Effects of surgical and pharmacological management of otitis media with effusion in children admitted to the Otolaryngology Department of the Medical University of Wroclaw. Przeglad Pediatryczny. 2001;31(3):215-8.
243 Povedano Rodriguez V, Seco Pinero MJ, Jurado Ramos A, et al. Efficacy of topical ciprofloxacin in the treatment of chronic otorrhea. Acta Otorrinolaringol Esp. Jan–Feb. 1995;46(1):15-8. [pmid: 7734157].
244 Racic G, Sprem N. The fascia and perichondrium in reconstructive surgery of the middle ear. Laryngol Rhinol Otol (Stuttg). Sep. 1986;65(9):496-8. [pmid: 3784729].
245 Roede J, Strutz J. Timely therapy of chronic otitis media. Z Arztl Fortbild (Jena). Jun. 1994;88(5–6):367-71. [pmid: 8091805].
246 Sagnelli M, Marzullo C, Pollastrini L, et al. Secretory otitis media: current aspects and therapeutic role of adenoidectomy. Medicina (Firenze). Jan–Mar. 1990;10(1):16-22. [pmid: 2199743].
247 Sanchez Gonzalez A, Gonzalez Galindo T. An open, comparative study of treatment of chronic middle ear otitis with levofloxacine vs amoxicillin/clavulanate. Investigacion Medica Internacional. 2001:33-6.
248 Sankovic S, Dergenc R. Surgical treatment of secretory otitis media: persistent perforation as a rare complication. Srp Arh Celok Lek. Jan–Feb. 1999;127(1–2):32-4. [pmid: 10377838].
249 Sarkar S, Roychoudhury A, Roychaudhuri BK. Tympanoplasty in children. Eur Arch Otorhinolaryngol. May. 2009;266(5):627-33. [pmid: 19159942].
250 Schrom T, Klaring S, Sedlmaier B. Treatment of chronic tube dysfunction. Use of the tube conductor. HNO. Nov. 2007;55(11):871-5. [pmid: 17279418].
251 Sedlmaier B, Jivanjee A, Gutzler R, et al. Duration of middle ear ventilation after laser myringotomy with the CO2 laser otoscope Otoscan. HNO. Jun. 2001;49(6):447-53. [pmid: 11450511].
252 Sevin F. Particularity of otitis media with effusion in cleft palate. Arch Pediatr. Jun. 2010;17(6):792-3. [pmid: 20654896].
253 Somekawa Y, Kobayashi K, Yamaguchi T, et al. Long-term result of grommets in children with secretory otitis media. Nippon Jibiinkoka Gakkai Kaiho. Mar. 1985;88(3):261-6. [pmid: 4040160].
254 Stangerup SE, Sederberg-Olsen J, Balle VH. Treatment with the Otovent device in tubal dysfunction and secretory otitis media in children. Ugeskr Laeger. Oct. 21. 1991;153(43):3008-9. [pmid: 1801386].
255 Stura M, Ivani G. Insertion of trans-tympanic drainage in muco-gelatinous otitis in children. Minerva Pediatr. Jul. 31. 1987;39(13–14):617-20. [pmid: 3670236].
256 Subbotina MV, Kunitsina MN, Buksha IA, et al. The use of sinupret in the combined treatment of acute otitis media in children. Vestn Otorinolaringol. 2009;(2):43-5. [pmid: 19491798].
257 Terazono T, Oshima W, Kume T, et al. Use of a butterfly ventilation tube in the treatment of otitis media with effusion. Nihon Jibiinkoka Gakkai Kaiho. May. 1991;94(5):699-704. [pmid: 1880643].
258 Tos M. Operative therapy for chronic otitis media and middle ear cholesteatoma with preservation of the posterior auditory canal wall ("intact wall technique") (author's transl). HNO. Jul. 1978;26(7):217-23. [pmid: 681183].
259 Tran Ba Huy P, Sauvaget E, Portier F. Seromucous otitis. Ann Otolaryngol Chir Cervicofac. Jul. 2007;124(3):120-5. [pmid: 17434139].
260 Vivian R. Recurrent secretory otitis media and adenoidism. A retrospective study of the results observed with the medical and surgical therapy of 1250 children. Recenti Prog Med. Oct. 1994;85(10):481-4. [pmid: 7809461].
261 Wiatr M, Oles K, Tomik J, et al. Prognostic factors in patients operated on eardrum perforation with intact ossicular chain. Otolaryngol Pol. Jul–Aug. 2011;65(4):266-71. [pmid: 22000143].
262 Wustrow T, Mannel M. Naturopathic therapy of acute otitis media in childhood. An alternative to primary antibiotic treatment. Zeitschrift Fur Phytotherapie. 2004:75-81.
263 Wustrow TP. Naturopathic therapy for acute otitis media. An alternative to the primary use of antibiotics. HNO. Aug. 2005;53(8):728-34. [pmid: 15614570].
264 Yu L, Ma X. Trans-external ear canal blow oxygen method. Lin Chuang Er Bi Yan Hou Ke Za Zhi. Jan. 2003;17(1):35-6. [pmid: 12725187].
265 Zhang ZG, Fan SC, Chen SJ, et al. Clinical significance of intact canal wall mastoidectomy combined with facial recess opening in the treatment of secretory otitis media of children. Zhonghua Er Bi Yan Hou Tou Jing Wai Ke Za Zhi. Sep. 2010;45(9):729-31. [pmid: 21092669].
266 Zheng Y, Xu L. The therapy of children with secretory otitis media by myringotomy with grommet insertion and the relevant management. Lin Chuang Er Bi Yan Hou Ke Za Zhi. Apr. 2001;15(4):155-6. [pmid: 12541636].
267 Zielhuis GA, Schilder A, van den Broek P. The spontaneous course of otitis media with effusion in young children. Ned Tijdschr Geneeskd. Sep. 21. 1991;135(38):1754-7. [pmid: 1922532].
268 Blanshard J, Maw A, Bawden R. The treatment of otitis media with effusion in children by autoinflation of the middle ear. 2nd European Congress of Oto-Rhino-Larynogology and cervico-facial surgery. 1992:31-7.

## Wrong Population

1 Management of acute otitis media and glue ear. Drug Ther Bull. Feb. 1995;33(2):12-5. [pmid: 7587982].
2 Akbari A, Mayhew A, Al-Alawi Manal A, et al. Interventions to improve outpatient referrals from primary care to secondary care. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
3 Allen Stephen J, Martinez Elizabeth G, Gregorio Germana V, et al. Probiotics for treating acute infectious diarrhoea. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2010.
4 Alpini D, Mattei V. A manually operated device for the treatment of residual middle ear effusion and Eustachian tube dysfunction. Audiological Medicine. 2008;6(2):166-8. Language: English. Entry Date: 20081017. Revision Date: 20091218. Publication Type: journal article.
5 Al-Qudah M, Dawes PJD. How we do it: Modified Wehrs incus ossiculoplasty. Clin Otolaryngol. 2005;30(5):461-4. [pmid: 16232254].
6 Altunc U, Pittler MH, Ernst E. Homeopathy for childhood and adolescence ailments: systematic review of randomized clinical trials (Structured abstract). Mayo Clin Proc. 2007:69-75. [pmid: 17285788].
7 Arguedas A, Loaiza C, Rodriguez F, et al. Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion. J Chemother. Feb. 1997;9(1):44-50. [pmid: 9106017].
8 Arguedas AG, Zaleska M, Stutman HR, et al. Comparative trial of cefprozil vs. amoxicillin clavulanate potassium in the treatment of children with acute otitis media with effusion. The Pediatric infectious disease journal. 1991:375-80. [pmid: 1906160].
9 Augustsson I, Engstrand I. Hearing loss as a sequel of secretory and acute otitis media as reflected by audiometric screening of Swedish conscripts. Int J Pediatr Otorhinolaryngol. Apr. 2006;70(4):703-10. [pmid: 16214225].
10 Austin DF. Adenoidectomy for secretory otitis media. Arch Otolaryngol Head Neck Surg. Aug. 1989;115(8):936-9. [pmid: 2751853].
11 Balkany TJ, Arenberg IK, Steenerson RL. Middle ear irrigation during insertion of ventilation tubes. Auris Nasus Larynx. Suppl 1. 1985;12:S265-7. [pmid: 3915206].
12 Balkany TJ, Arenberg IK, Steenerson RL. Ventilation tube surgery and middle ear irrigation. Laryngoscope. May. 1986;96(5):529-32. [pmid: 3517534].
13 Balkany TJ, Barkin RM, Suzuki BH, et al. A prospective study of infection following tympanostomy and tube insertion. Am J Otol. Apr. 1983;4(4):288-91. [pmid: 6344649].
14 Bensch CM, Strocel MC, Selkley K. Preoperative medication for pediatric tympanotomy: Necessary or not?. J Am Assoc Nurse Anesth. 1993;61(4):424-5.
15 Birch EE, Khoury JC, Berseth CL, et al. The impact of early nutrition on incidence of allergic manifestations and common respiratory illnesses in children. J Pediatr. 2010:902-6. 6.e1. [pmid: 20227721].
16 Bonuck KA, Freeman K, Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med. Sep. 2006;160(9):953-60. [pmid: 16953019].
17 Bottenfield GW, Rothstein EP, Kelsey DK, et al. Comparative evaluation of loracarbef and cefprozil in the treatment of infants and children with acute otitis media with effusion. Curr Ther Res Clin Exp. 1999:62-71.
18 Brownlee RC Jr, DeLoache WR, Cowan CC Jr, et al. Otitis media in children. Incidence, treatment, and prognosis in pediatric practice. J Pediatr. Oct. 1969;75(4):636-42. [pmid: 5809840].
19 Bulman CH, Brook SJ, Berry MG. A prospective randomized trial of adenoidectomy vs grommet insertion in the treatment of glue ear. Clin Otolaryngol Allied Sci. Apr. 1984;9(2):67-75. [pmid: 6380828].
20 Cannon S. External otitis:controlled therapeutic trial. Eye Ear Nose Throat Mon. 1970:186-9. [pmid: 4921300].
21 Caye-Thomasen P, Nielsen TR, Tos M. Bilateral myringoplasty in chronic otitis media. Laryngoscope. May. 2007;117(5):903-6. [pmid: 17473693].
22 Cengel S, Akyol MU. The role of topical nasal steroids in the treatment of children with otitis media with effusion and/or adenoid hypertrophy. Int J Pediatr Otorhinolaryngol. Apr. 2006;70(4):639-45. [pmid: 16169093].
23 Chen CY, Young YH, Hsu WC, et al. Failure of grommet insertion in post-irradiation otitis media with effusion. Ann Otol Rhinol Laryngol. Aug. 2001;110(8):746-8. [pmid: 11510732].
24 Chevretton E, Bingham BJ, Firman E. The prevention of tympanic membrane perforation following the removal of long-term Paparella type II ventilation tubes. Clin Otolaryngol Allied Sci. Oct. 1987;12(5):377-81. [pmid: 3427802].
25 Chole RA, Hubbell RN. Antimicrobial activity of silastic tympanostomy tubes impregnated with silver oxide. A double-blind randomized multicenter trial. Arch Otolaryngol Head Neck Surg. May. 1995;121(5):562-5. [pmid: 7727091].
26 Coates H, Chai F, Oates J. The use of surface treated and silver oxide impregnated tympanostomy tubes in reducing post-operative otorrhoea. Australian Journal of Otolaryngology. 1998:16-9.
27 Connolly AA, Picozzi GL, Browning GG. Randomized trial of neomycin/dexamethasone spray vs drop preparation for the treatment of active chronic mucosal otitis media. Clin Otolaryngol Allied Sci. Dec. 1997;22(6):529-31. [pmid: 9466064].
28 Corwin MJ, Weiner LB, Daniels D. Efficacy of oral antibiotics for the treatment of persistent otitis media with effusion. Int J Pediatr Otorhinolaryngol. Apr. 1986;11(2):109-12. [pmid: 3488978].
29 Cox RG, Nemish U, Ewen A, et al. Evidence-based clinical update: does premedication with oral midazolam lead to improved behavioural outcomes in children? (Structured abstract). Canadian Journal of Anesthesia. 2006:1213-9. [pmid: 17142656].
30 de Beer B, Snik A, Schilder AG, et al. The effect of otitis media in childhood on the development of middle ear admittance on reaching adulthood. Arch Otolaryngol Head Neck Surg. Sep. 2005;131(9):777-81. [pmid: 16172353].
31 de Beer BA, Schilder AG, Ingels K, et al. Hearing loss in young adults who had ventilation tube insertion in childhood. Ann Otol Rhinol Laryngol. Jun. 2004;113(6):438-44. [pmid: 15224825].
32 De Beer BA, Schilder AG, Zielhuis GA, et al. Natural course of tympanic membrane pathology related to otitis media and ventilation tubes between ages 8 and 18 years. Otol Neurotol. Sep. 2005;26(5):1016-21. [pmid: 16151352].
33 Denoyelle F, Roger G, Chauvin P, et al. Myringoplasty in children: predictive factors of outcome. Laryngoscope. Jan. 1999;109(1):47-51. [pmid: 9917039].
34 Derkay CS, Wadsworth JT, Darrow DH, et al. Tube placement: a prospective, randomized double-blind study. Laryngoscope. Jan. 1998;108(1 Pt 1):97-101. [pmid: 9432075].
35 Elluru RG, Dhanda R, Neely JG, et al. Anterior subannular T-tube for prolonged middle ear ventilation during tympanoplasty: evaluation of efficacy and complications. Otol Neurotol. Nov. 2001;22(6):761-5. [pmid: 11698792].
36 Englender M, Somech E, Harell M. Laser myringotomy (L-myringotomy) and ventilating tubes: A preliminary comparative study. Lasers in Medical Science. 1999:62-6.
37 Esposito S, D'Errico G, Montanaro C. Topical and oral treatment of chronic otitis media with ciprofloxacin. A preliminary study. Arch Otolaryngol Head Neck Surg. May. 1990;116(5):557-9. [pmid: 2328112].
38 Esposito S, Noviello S, D'Errico G, et al. Topical ciprofloxacin vs intramuscular gentamicin for chronic otitis media. Arch Otolaryngol Head Neck Surg. Aug. 1992;118(8):842-4. [pmid: 1642836].
39 Fernee B, Sockalingam R. Outcomes of ENT surgery for middle-ear disease in aboriginal populations living in remote communities: A comparison between pre and post operative audiometric results. Australian Journal of Otolaryngology. 2002;5(1):6-13.
40 Fishman I, Sykes KJ, Horvat R, et al. Demographics and microbiology of otorrhea through patent tubes failing ototopical and/or oral antibiotic therapy. Otolaryngol Head Neck Surg. Dec. 2011;145(6):1025-9. [pmid: 21846926].
41 Fliss DM, Dagan R, Houri Z, et al. Medical management of chronic suppurative otitis media without cholesteatoma in children. J Pediatr. Jun. 1990;116(6):991-6. [pmid: 2189979].
42 Fombeur JP, Barrault S, Koubbi G, et al. Study of the efficacy and safety of ciprofloxacin in the treatment of chronic otitis. Chemotherapy. 1994:29-34. [pmid: 7805428].
43 Fradis M, Brodsky A, Ben-David J, et al. Chronic otitis media treated topically with ciprofloxacin or tobramycin. Arch Otolaryngol Head Neck Surg. Oct. 1997;123(10):1057-60. [pmid: 9339980].
44 Friese KH, Kruse S, Ludtke R, et al. The homoeopathic treatment of otitis media in children--comparisons with conventional therapy. Int J Clin Pharmacol Ther. Jul. 1997;35(7):296-301. [pmid: 9247843].
45 Friese KH, Kruse S, Moeller H. Acute otitis media in children: a comparison of conventional and homeopathic treatment. Biomed Ther. 1997:113-6.
46 Gehanno P. Multicenter study of the efficacy and safety of oral ciprofloxacin in the treatment of chronic suppurative otitis media in adults. The French Study Group. Otolaryngol Head Neck Surg. Jul. 1997;117(1):83-90. [pmid: 9230329].
47 Gersdorff M, Garin P, Decat M, et al. Myringoplasty: long-term results in adults and children. Am J Otol. Jul. 1995;16(4):532-5. [pmid: 8588656].
48 Gluth MB, McDonald DR, Weaver AL, et al. Management of eustachian tube dysfunction with nasal steroid spray: a prospective, randomized, placebo-controlled trial. Arch Otolaryngol Head Neck Surg. May. 2011;137(5):449-55. [pmid: 21576556].
49 Gluth MB, Motakef S, Friedland PL, et al. Incus replacement malleostapedotomy in quiescent chronic otitis media with a mobile stapes footplate: an alternative to TORP in select cases. Otol Neurotol. Feb. 2011;32(2):242-5. [pmid: 21150689].
50 Goldstein NA, Roland JT Jr, Sculerati N. Complications of tympanostomy tubes in an inner city clinic population. Int J Pediatr Otorhinolaryngol. Jan. 1996;34(1–2):87-99. [pmid: 8770676].
51 Gooch WM 3rd, Blair E, Puopolo A, et al. Clinical comparison of cefuroxime axetil suspension and amoxicillin/clavulanate suspension in the treatment of pediatric patients with acute otitis media with effusion. Clin Ther. Sep–Oct. 1995;17(5):838-51. [pmid: 8595636].
52 Goode RL. CO2 laser myringotomy. Laryngoscope. Apr. 1982;92(4):420-3. [pmid: 7200178].
53 Gordts F, Clement PA, Derde MP. Lens tube vs Donaldson tube: results of a prospective study comparing a new with a conventional ventilation tube. Clin Otolaryngol Allied Sci. Oct. 1993;18(5):410-4. [pmid: 8877210].
54 Granath A, Rynnel-Dagoo B, Backheden M, et al. Tube associated otorrhea in children with recurrent acute otitis media; results of a prospective randomized study on bacteriology and topical treatment with or without systemic antibiotics. Int J Pediatr Otorhinolaryngol. Aug. 2008;72(8):1225-33. [pmid: 18565598].
55 Guneren E, Ozsoy Z, Ulay M, et al. A comparison of the effects of Veau-Wardill-Kilner palatoplasty and furlow double-opposing Z-plasty operations on eustachian tube function. Cleft Palate Craniofac J. May. 2000;37(3):266-70. [pmid: 10830805].
56 Guttenplan MD, Tom LW, DeVito MA, et al. Radial versus circumferential incision in myringotomy and tube placement. Int J Pediatr Otorhinolaryngol. May. 1991;21(3):211-5. [pmid: 1869374].
57 Hall JW, Grose JH, Buss E, et al. The effect of otitis media with effusion on perceptual masking. Arch Otolaryngol Head Neck Surg. Oct. 2003;129(10):1056-62. [pmid: 14568787].
58 Hall JW 3rd, Grose JH, Pillsbury HC. Long-term effects of chronic otitis media on binaural hearing in children. Arch Otolaryngol Head Neck Surg. Aug. 1995;121(8):847-52. [pmid: 7619408].
59 Hamaguchi Y, Sakakura Y, Majima Y, et al. Kinetics of lysosomal protease activity in human otitis media with effusion. Am J Otolaryngol. Jul–Aug. 1987;8(4):194-8. [pmid: 2443031].
60 Hammaren-Malmi S, Saxen H, Tarkkanen J, et al. Adenoidectomy does not significantly reduce the incidence of otitis media in conjunction with the insertion of tympanostomy tubes in children who are younger than 4 years: a randomized trial. Pediatrics. Jul. 2005;116(1):185-9. [pmid: 15995051].
61 Handler SD, Miller L, Potsic WP, et al. A prospective study of titanium ventilation tubes. Int J Pediatr Otorhinolaryngol. Oct. 1988;16(1):55-60. [pmid: 3203987].
62 Harrison CJ. Changes in treatment strategies for acute otitis media after full implementation of the pneumococcal seven valent conjugate vaccine. Pediatr Infect Dis J. Aug. 2003;22(8 Suppl):S120-30. [pmid: 14566998].
63 Harrison CJ, Belhorn TH. Antibiotic treatment failures in acute otitis media. Pediatr Ann. Nov. 1991;20(11):600-1. 3. 8. [pmid: 1956705].
64 Hassan ME, Askar S. Does palatal muscle reconstruction affect the functional outcome of cleft palate surgery?. Plast Reconstr Surg. May. 2007;119(6):1859-65. [pmid: 17440366].
65 Ho WK, Wei WI, Kwong DL, et al. Randomized evaluation of the audiologic outcome of ventilation tube insertion for middle ear effusion in patients with nasopharyngeal carcinoma. J Otolaryngol. Oct. 2002;31(5):287-93. [pmid: 12512893].
66 Hogan SC, Meyer SE, Moore DR. Binaural unmasking returns to normal in teenagers who had otitis media in infancy. Audiol Neurootol. Mar–Apr. 1996;1(2):104-11. [pmid: 9390794].
67 Homoe P, Sorensen HC, Tos M. Mobile, one stage, bilateral ear surgery for chronic otitis media patients in remote areas. J Laryngol Otol. Oct. 2009;123(10):1108-13. [pmid: 19575840].
68 Howie VM, Ploussard JH. Efficacy of fixed combination antibiotics versus separate components in otitis media. Effectiveness of erythromycin estrolate, triple sulfonamide, ampicillin, erythromycin estolate- triple sulfonamide, and placebo in 280 patients with acute otitis media under two and one-half years of age. Clin Pediatr (Phila). Apr. 1972;11(4):205-14. [pmid: 4537206].
69 Hubbard TW, Paradise JL, McWilliams BJ, et al. Consequences of unremitting middle-ear disease in early life. Otologic, audiologic, and developmental findings in children with cleft palate. N Engl J Med. Jun. 13. 1985;312(24):1529-34. [pmid: 4039792].
70 Hug JE. A planimetric study of temporal bone pneumatization. Arch Otorhinolaryngol. 1986;243(5):304-8. [pmid: 3813966].
71 Hug JE, Pfaltz CR. Temporal bone pneumatization. A planimetric study. Arch Otorhinolaryngol. 1981;233(2):145-56. [pmid: 7198439].
72 Hwang C, Chien C, Lin H, et al. Laser myringotomy for otitis media with effusion in nasopharyngeal carcinoma patients. Otolaryngology-Head & Neck Surgery. 2005;132(6):924-7. Language: English. Entry Date: 20051125. Revision Date: 20091218. Publication Type: journal article. [pmid: 15944565].
73 Iino Y, Nagamine H, Kakizaki K, et al. Effectiveness of instillation of triamcinolone acetonide into the middle ear for eosinophilic otitis media associated with bronchial asthma. Ann Allergy Asthma Immunol. Dec. 2006;97(6):761-6. [pmid: 17201235].
74 Ilicali OC, Keles N, Deer K, et al. Evaluation of the effect of passive smoking on otitis media in children by an objective method: urinary cotinine analysis. Laryngoscope. Jan. 2001;111(1):163-7. [pmid: 11192887].
75 Ilicali OC, Keles N, Deger K, et al. Relationship of passive cigarette smoking to otitis media. Arch Otolaryngol Head Neck Surg. Jul. 1999;125(7):758-62. [pmid: 10406313].
76 Jang CH, Song CH, Wang PC. Topical vancomycin for chronic suppurative otitis media with methicillin-resistant Staphylococcus aureus otorrhoea. J Laryngol Otol. Aug. 2004;118(8):645-7. [pmid: 15453944].
77 Jenner PN, Tierney HE, Carle WK. A general practice study of a new approach to the use of antibiotics in the treatment of acute otitis media in children aged three and over. Br J Clin Pract. 1987:820-6. [pmid: 3446282].
78 Kadhim AL, Spilsbury K, Semmens JB, et al. Adenoidectomy for middle ear effusion: a study of 50,000 children over 24 years. Laryngoscope. Mar. 2007;117(3):427-33. [pmid: 17279052].
79 Kasemsuwan L, Clongsuesuek P. A double blind, prospective trial of topical ciprofloxacin versus normal saline solution in the treatment of otorrhoea. Clin Otolaryngol Allied Sci. Feb. 1997;22(1):44-6. [pmid: 9088679].
80 Kay DJ, Nelson M, Rosenfeld RM. Meta-analysis of tympanostomy tube sequelae. Otolaryngol Head Neck Surg. Apr. 2001;124(4):374-80. [pmid: 11283489].
81 Kilic R, Safak MA, Ozdek A, et al. Effect of 23 valent pneumococcal polysaccharide and Haemophilus influenza conjugated vaccines on the clinical course of otitis media with effusion. Laryngoscope. 2002;112(11):2042-5. [pmid: 12439177].
82 Kinnari TJ, Jero J. Experimental and clinical experience of albumin coating of tympanostomy tubes. Otolaryngol Head Neck Surg. Oct. 2005;133(4):596-600. [pmid: 16213935].
83 Kinnari TJ, Rihkanen H, Laine T, et al. Role of albumin coating of tympanostomy tubes: long-term clinical evaluation. Laryngoscope. Dec. 2007;117(12):2213-7. [pmid: 17921900].
84 Kjellman NI, Harder H, Hansson LO, et al. Allergy, otitis media and serum immunoglobulins after adenoidectomy. Acta Paediatr Scand. Nov. 1978;67(6):717-23. [pmid: 716870].
85 Klein JO. Management of otitis media with antimicrobial agents. Curr Clin Top Infect Dis. 2000;20:174-88. [pmid: 10943524].
86 Klingensmith MR, Strauss M, Conner GH. A comparison of retention and complication rates of large-bore (Paparella II) and small-bore middle ear ventilating tubes. Otolaryngol Head Neck Surg. Jun. 1985;93(3):322-30. [pmid: 3927225].
87 Kocaturk S, Yardimci S, Yildirim A, et al. Preventive therapy for postoperative purulent otorrhea after ventilation tube insertion. Am J Otolaryngol. Mar–Apr. 2005;26(2):123-7. [pmid: 15742266].
88 Koivunen P, Uhari M, Luotonen J, et al. Adenoidectomy versus chemoprophylaxis and placebo for recurrent acute otitis media in children aged under 2 years: randomised controlled trial. BMJ. Feb. 28. 2004;328(7438):487. [pmid: 14769785].
89 Lawhorn CD, Bower CM, Brown RE Jr, et al. Topical lidocaine for postoperative analgesia following myringotomy and tube placement. Int J Pediatr Otorhinolaryngol. Mar. 1996;35(1):19-24. [pmid: 8882105].
90 Le CT, Freeman DW, Fireman BH. Evaluation of ventilating tubes and myringotomy in the treatment of recurrent or persistent otitis media. Pediatr Infect Dis J. Jan. 1991;10(1):2-11. [pmid: 2003051].
91 Leach A, Wood Y, Gadil E, et al. Topical ciprofloxin versus topical framycetin-gramicidin-dexamethasone in Australian aboriginal children with recently treated chronic suppurative otitis media: a randomized controlled trial. Pediatr Infect Dis J. Aug. 2008;27(8):692-8. [pmid: 18664984].
92 Legent F, Bordure P, Beauvillain C, et al. Controlled prospective study of oral ciprofloxacin versus amoxycillin/clavulanic acid in chronic suppurative otitis media in adults. Chemotherapy. Suppl 1. 1994;40:16-23. [pmid: 7805426].
93 Leiberman A, Fliss DM, Dagan R. Medical treatment of chronic suppurative otitis media without cholesteatoma in children--a two-year follow-up. Int J Pediatr Otorhinolaryngol. Jul. 1992;24(1):25-33. [pmid: 1399301].
94 Lildholdt T. Secretory otitis media. The significance of negative middle ear pressure and the results of a controlled study of ventilation tubes. Dan Med Bull. Nov. 1983;30(6):408-15. [pmid: 6357648].
95 Lildholdt T, Felding JU, Juul A, et al. Efficacy of perioperative ceftazidime in the surgical treatment of chronic otitis media due to Pseudomonas aeruginosa. Preliminary report of a prospective, controlled study. Arch Otorhinolaryngol. 1986;243(3):167-9. [pmid: 3530224].
96 Luntz M, Teszler CB, Shpak T. Cochlear implantation in children with otitis media: second stage of a long-term prospective study. Int J Pediatr Otorhinolaryngol. Mar. 2004;68(3):273-80. [pmid: 15129937].
97 Mackenzie IJ. Factors affecting the extrusion rates of ventilation tubes. J R Soc Med. Sep. 1984;77(9):751-3. [pmid: 6541254].
98 Mandel EM, Bluestone CD, Takahashi H, et al. Effect of adenoidectomy on eustachian tube function. Preliminary results of a randomized clinical trial. Adv Otorhinolaryngol. 1992;47:227-31. [pmid: 1456139].
99 Mandel EM, Casselbrant ML, Rockette HE, et al. Efficacy of antimicrobial prophylaxis for recurrent middle ear effusion. Pediatr Infect Dis J. Dec. 1996;15(12):1074-82. [pmid: 8970215].
100 Mattila PS, Joki-Erkkila VP, Kilpi T, et al. Prevention of otitis media by adenoidectomy in children younger than 2 years. Arch Otolaryngol Head Neck Surg. Feb. 2003;129(2):163-8. [pmid: 12578443].
101 McLinn SE. Recurrence of otitis media after antibiotic therapy: comparison of cephradine and amoxycillin. J Int Med Res. 1979;7(6):546-50. [pmid: 391628].
102 McLinn SE. Randomized, open label, multicenter trial of cefixime compared with amoxicillin for treatment of acute otitis media with effusion. Pediatr Infect Dis J. Oct. 1987;6(10):997-1001. [pmid: 3320928].
103 McLinn SE, Moskal M, Goldfarb J, et al. Comparison of cefuroxime axetil and amoxicillin-clavulanate suspensions in treatment of acute otitis media with effusion in children. Antimicrob Agents Chemother. 1994;38(2):315-8. [pmid: 8192458].
104 McQueen CT, Burke JR, Wellendorf TG, et al. Improved hearing results from stapedotomy with myringotomy. N C Med J. May–Jun. 1996;57(3):176-8. [pmid: 8935366].
105 Merrick GD, Kunjur J, Watts R, et al. The effect of early insertion of grommets on the development of speech in children with cleft palates. Br J Oral Maxillofac Surg. Oct. 2007;45(7):527-33. [pmid: 17383059].
106 Migirov L, Amir A, Kronenberg J. The influence of mastoidectomy on natural history of secretory otitis media in cochlear implant children. ORL J Otorhinolaryngol Relat Spec. 2006;68(3):156-8. [pmid: 16465069].
107 Morpeth JF, Bent JP, Watson T. A comparison of cortisporin and ciprofloxacin otic drops as prophylaxis against post-tympanostomy otorrhea. Int J Pediatr Otorhinolaryngol. Nov. 1. 2001;61(2):99-104. [pmid: 11589975].
108 Mueller DT, Isaacson G. Staged tympanostomy tube placement facilitates pediatric cholesteatoma management. Int J Pediatr Otorhinolaryngol. Feb. 2008;72(2):167-71. [pmid: 18023884].
109 Muenker G. Results after treatment of otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):308-11. [pmid: 6778334].
110 Nawasreh O, Al-Wedyan IA. Prophylactic ciprofloxacin drops after tympanostomy tube insertion. Saudi Med J. Jan. 2004;25(1):38-40. [pmid: 14758376].
111 Nguyen LH, Manoukian JJ, Yoskovitch A, et al. Adenoidectomy: selection criteria for surgical cases of otitis media. Laryngoscope. May. 2004;114(5):863-6. [pmid: 15126745].
112 O'Brien MA, Prosser LA, Paradise JL, et al. New vaccines against otitis media: projected benefits and cost-effectiveness. Pediatrics. Jun. 2009;123(6):1452-63. [pmid: 19482754].
113 Odio CM, Kusmiesz H, Shelton S, et al. Comparative treatment trial of augmentin versus cefaclor for acute otitis media with effusion. Pediatrics. May. 1985;75(5):819-26. [pmid: 4039433].
114 Odutoye T, McGilligan A, Robb PJ. Aseptic surgical technique and postgrommet otorrhoea. Int J Pediatr Otorhinolaryngol. 2003;67(SUPPL 1):S233-S5. [pmid: 14662203].
115 O'Leary S, Veldman JE. Revision surgery for chronic otitis media: recurrent-residual disease and hearing. J Laryngol Otol. Dec. 2002;116(12):996-1000. [pmid: 12537610].
116 Oomen KP, Rovers MM, van den Akker EH, et al. Effect of adenotonsillectomy on middle ear status in children. Laryngoscope. Apr. 2005;115(4):731-4. [pmid: 15805889].
117 O'Reilly RC, He Z, Bloedon E, et al. The role of extraesophageal reflux in otitis media in infants and children. Laryngoscope. Jul. 2008;118(7 Part 2 Suppl 116):1-9. [pmid: 18594333].
118 Ozagar A, Koc A, Ciprut A, et al. Effects of topical otic preparations on hearing in chronic otitis media. Otolaryngol Head Neck Surg. Oct. 1997;117(4):405-8. [pmid: 9339804].
119 Ozbek C, Somuk T, Ciftci O, et al. Management of facial nerve paralysis in noncholesteatomatous chronic otitis media. B-ENT. 2009;5(2):73-7. [pmid: 19670593].
120 Papsin BC, Bailey CM, Albert DM, et al. Otitis media with effusion in paediatric cochlear implantees: the role of peri-implant grommet insertion. Int J Pediatr Otorhinolaryngol. Dec. 5. 1996;38(1):13-9. [pmid: 9119589].
121 Paradise JL, Bluestone CD. Early treatment of the universal otitis media of infants with cleft palate. Pediatrics. Jan. 1974;53(1):48-54. [pmid: 4809194].
122 Paradise JL, Bluestone CD, Colborn DK, et al. Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: parallel randomized clinical trials in children not previously treated with tympanostomy tubes. JAMA. Sep. 8. 1999;282(10):945-53. [pmid: 10485679].
123 Paradise JL, Bluestone CD, Rogers KD, et al. Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA. Apr. 18. 1990;263(15):2066-73. [pmid: 2181158].
124 Pestieau SR, Quezado ZM, Johnson YJ, et al. The effect of dexmedetomidine during myringotomy and pressure-equalizing tube placement in children. Paediatr Anaesth. 2011. [Epub ahead of print].
125 Phillips CJ, Burrell A, Moore RA, et al. Mucodyne: The economics of preventing surgery for grommets. Journal of Medical Economics. 1999;2(167–176):167-76.
126 Pichichero ME, Berghash LR, Hengerer AS. Anatomic and audiologic sequelae after tympanostomy tube insertion or prolonged antibiotic therapy for otitis media. Pediatr Infect Dis J. Nov. 1989;8(11):780-7. [pmid: 2594453].
127 Poetker DM, Lindstrom DR, Patel NJ, et al. Ofloxacin otic drops vs neomycin-polymyxin B otic drops as prophylaxis against early postoperative tympanostomy tube otorrhea. Arch Otolaryngol Head Neck Surg. Dec. 2006;132(12):1294-8. [pmid: 17178938].
128 Principi N. Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microbiol Infect Dis. Aug. 1995;14(8):669-76. [pmid: 8565983].
129 Qvarnberg Y, Kantola O, Valtonen H, et al. Bacterial findings in middle ear effusion in children. Otolaryngol Head Neck Surg. Feb. 1990;102(2):118-21. [pmid: 2113235].
130 Raj A, Sayal A, Rathore PK, et al. Sutureless tympanoplasty using acellular dermis. Am J Otolaryngol. Mar–Apr. 2011;32(2):96-9. [pmid: 20392523].
131 Richards M, Giannoni C. Quality-of-life outcomes after surgical intervention for otitis media. Arch Otolaryngol Head Neck Surg. Jul. 2002;128(7):776-82. [pmid: 12117333].
132 Robinson PJ, Lodge S, Goligher J, et al. Secretory otitis media and mastoid air cell development. Int J Pediatr Otorhinolaryngol. Jan. 1993;25(1–3):13-8. [pmid: 8436456].
133 Robson AK, Blanshard JD, Jones K, et al. A conservative approach to the management of otitis media with effusion in cleft palate children. J Laryngol Otol. Sep. 1992;106(9):788-92. [pmid: 1431515].
134 Roland PS, Anon JB, Moe RD, et al. Topical ciprofloxacin/dexamethasone is superior to ciprofloxacin alone in pediatric patients with acute otitis media and otorrhea through tympanostomy tubes. Laryngoscope. Dec. 2003;113(12):2116-22. [pmid: 14660913].
135 Roland PS, Dohar JE, Lanier BJ, et al. Topical ciprofloxacin/dexamethasone otic suspension is superior to ofloxacin otic solution in the treatment of granulation tissue in children with acute otitis media with otorrhea through tympanostomy tubes. Otolaryngol Head Neck Surg. Jun. 2004;130(6):736-41. [pmid: 15195060].
136 Rombout J, Pauw BK. Radical revision mastoidectomy for chronic otitis media without cholesteatoma: the relevance of excenteration of all rest cells. J Laryngol Otol. Aug. 1999;113(8):710-3. [pmid: 10748843].
137 Rosenfeld RM, Bhaya MH, Bower CM, et al. Impact of tympanostomy tubes on child quality of life. Arch Otolaryngol Head Neck Surg. May. 2000;126(5):585-92. [pmid: 10807325].
138 Ruohola A, Heikkinen T, Meurman O, et al. Antibiotic treatment of acute otorrhea through tympanostomy tube: randomized double-blind placebo-controlled study with daily follow-up. Pediatrics. May. 2003;111(5 Pt 1):1061-7. [pmid: 12728089].
139 Ryding M, Konradsson K, White P, et al. Hearing loss after "refractory" secretory otitis media. Acta Otolaryngol. Mar. 2005;125(3):250-5. [pmid: 15966692].
140 Rynnel-Dagoo B, Ahlbom A, Schiratzki H. Effects of adenoidectomy: a controlled two-year follow-up. Ann Otol Rhinol Laryngol. Mar–Apr. 1978;87(2 Pt 1):272-8. [pmid: 646300].
141 Salami A, Mora R, Dellepiane M, et al. Piezosurgery versus microdrill in intact canal wall mastoidectomy. European archives of oto-rhino-laryngology : official journal of the European Federation of Oto-Rhino-Laryngological Societies (EUFOS) : affiliated with the German Society for Oto-Rhino-Laryngology - Head and Neck Surgery. 2010:1705-11. [pmid: 20577753].
142 Saliba I, Boutin T, Arcand P, et al. Advantages of subannular tube vs repetitive transtympanic tube technique. Arch Otolaryngol Head Neck Surg. Dec. 2011;137(12):1210-6. [pmid: 22183899].
143 Sawyer CE, Evans RL, Boline PD, et al. A feasibility study of chiropractic spinal manipulation versus sham spinal manipulation for chronic otitis media with effusion in children. J Manipulative Physiol Ther. 1999;22(5):292-8. Language: English. Entry Date: 19990801. Revision Date: 20091218. Publication Type: journal article. [pmid: 10395431].
144 Schuller DE. Prophylaxis of otitis media in asthmatic children. Pediatr Infect Dis. Jul–Aug. 1983;2(4):280-3. [pmid: 6889154].
145 Severeid LR. A longitudinal study of the efficacy of adenoidectomy in children with cleft palate and secretory otitis media. Trans Am Acad Ophthalmol Otolaryngol. Sep–Oct. 1972;76(5):1319-24. [pmid: 4666581].
146 Shaw R, Richardson D, McMahon S. Conservative management of otitis media in cleft palate. J Craniomaxillofac Surg. Oct. 2003;31(5):316-20. [pmid: 14563333].
147 Sheahan P, Blayney AW, Sheahan JN, et al. Sequelae of otitis media with effusion among children with cleft lip and/or cleft palate. Clin Otolaryngol Allied Sci. Dec. 2002;27(6):494-500. [pmid: 12472518].
148 Shekelle PG, Takata G, Newberry SJ, et al. Management of Acute Otitis Media: Update. Evidence Report/Technology Assessment No. 198. Prepared by the RAND Evidence-Based Practice Center under Contract No. 290 2007 10056 I. Rockville, MD. Agency for Healthcare Research and Quality. November. 2010. http://www.mrw.interscience.wiley.com/cochrane/cldare/articles/DARE-12010008199/frame.html.
149 Sher L, Arguedas A, Husseman M, et al. Randomized, investigator-blinded, multicenter, comparative study of gatifloxacin versus amoxicillin/clavulanate in recurrent otitis media and acute otitis media treatment failure in children. Pediatr Infect Dis J. Apr. 2005;24(4):301-8. [pmid: 15818288].
150 Shinkawa A, Sakai M, Tamura Y, et al. Canal-down tympanoplasty; one-stage tympanoplasty with mastoid obliteration, for non-cholesteatomatous chronic otitis media associated with osteitis. Tokai J Exp Clin Med. Mar. 1998;23(1):19-23. [pmid: 9972532].
151 Shone GR, Griffith IP. Titanium grommets: a trial to assess function and extrusion rates. The Journal of laryngology and otology. 1990:197-9. [pmid: 2341773].
152 Singh GB, Sharma A, Singh N. Role of transtympanic myringoplasty in modern otology. J Otolaryngol. Dec. 2006;35(6):408-12. [pmid: 17380836].
153 Smith AW, Hatcher J, Mackenzie IJ, et al. Randomised controlled trial of treatment of chronic suppurative otitis media in Kenyan schoolchildren. Lancet. Oct. 26. 1996;348(9035):1128-33. [pmid: 8888166].
154 Smith LK, Gubbels SP, MacArthur CJ, et al. The effect of the palatoplasty method on the frequency of ear tube placement. Arch Otolaryngol Head Neck Surg. Oct. 2008;134(10):1085-9. [pmid: 18936356].
155 Somekh E, Cordova Z. Ceftazidime versus aztreonam in the treatment of pseudomonal chronic suppurative otitis media in children. Scand J Infect Dis. 2000;32(2):197-9. [pmid: 10826908].
156 Spilsbury K, Miller I, Semmens JB, et al. Factors associated with developing cholesteatoma: A study of 45,980 children with middle ear disease. Laryngoscope. 2010;120(3):625-30. [pmid: 20058316].
157 Spiro DM, King WD, Arnold DH, et al. A randomized clinical trial to assess the effects of tympanometry on the diagnosis and treatment of acute otitis media. Pediatrics. Jul. 2004;114(1):177-81. [pmid: 15231925].
158 Spraggs PD, Robinson PJ, Ryan R, et al. A prospective randomised trial of the use of sodium bicarbonate and hydrogen peroxide ear drops to clear a blocked tympanostomy tube. Int J Pediatr Otorhinolaryngol. Mar. 1995;31(2–3):207-14. [pmid: 7782178].
159 Straetemans M, Palmu A, Auranen K, et al. The effect of a pneumococcal conjugate vaccine on the risk of otitis media with effusion at 7 and 24 months of age. Int J Pediatr Otorhinolaryngol. Nov. 2003;67(11):1235-42. [pmid: 14597376].
160 Sundberg M, Peebo M, Oberg PA, et al. Diffuse reflectance spectroscopy of the human tympanic membrane in otitis media. Physiol Meas. Dec. 2004;25(6):1473-83. [pmid: 15712725].
161 Supiyaphun P, Kerekhanjanarong V, Koranasophonepun J, et al. Comparison of ofloxacin otic solution with oral amoxycillin plus chloramphenicol ear drop in treatment of chronic suppurative otitis media with acute exacerbation. J Med Assoc Thai. Jan. 2000;83(1):61-8. [pmid: 10710871].
162 Tami TA, Kennedy KS, Harley E. A clinical evaluation of gold-plated tubes for middle-ear ventilation. Arch Otolaryngol Head Neck Surg. Sep. 1987;113(9):979-80. [pmid: 3300707].
163 Tano K, Grahn Hakansson E, Holm SE, et al. A nasal spray with alpha-haemolytic streptococci as long term prophylaxis against recurrent otitis media. Int J Pediatr Otorhinolaryngol. Jan. 11. 2002;62(1):17-23. [pmid: 11738689].
164 Tavin ME, Gordon M, Ruben RJ. Hearing results with the use of different tympanostomy tubes: a prospective study. Int J Pediatr Otorhinolaryngol. Feb. 1988;15(1):39-50. [pmid: 3372141].
165 Taylor JA, Jacobs J. Homeopathic ear drops as an adjunct to standard therapy in children with acute otitis media. Homeopathy. Jul. 2011;100(3):109-15. [pmid: 21784326].
166 Taylor PS, Faeth I, Marks MK, et al. Cost of treating otitis media in Australia. Expert Rev Pharmacoecon Outcomes Res. Apr. 2009;9(2):133-41. [pmid: 19402800].
167 Thoroddsen E, Marr C, Efthymiopoulos C, et al. Concentration of cefuroxime in middle ear effusion of children with acute otitis media. Pediatr Infect Dis J. Oct. 1997;16(10):959-62. [pmid: 9380472].
168 Thorp MA, Gardiner IB, Prescott CA. Burow's solution in the treatment of active mucosal chronic suppurative otitis media: determining an effective dilution. J Laryngol Otol. Jun. 2000;114(6):432-6. [pmid: 10962675].
169 Tong MC, Woo JK, van Hasselt CA. A double-blind comparative study of ofloxacin otic drops versus neomycin-polymyxin B-hydrocortisone otic drops in the medical treatment of chronic suppurative otitis media. J Laryngol Otol. Apr. 1996;110(4):309-14. [pmid: 8733449].
170 Tong MC, Yue V, Ku PK, et al. Preoperative topical ofloxacin solution for tympanoplasty: a randomized, controlled study. Otol Neurotol. Jan. 2002;23(1):18-20. [pmid: 11773839].
171 Truy E, Naiman AN, Pavillon C, et al. Hydroxyapatite versus titanium ossiculoplasty. Otol Neurotol. Jun. 2007;28(4):492-8. [pmid: 17529851].
172 Tutkun A, Ozagar A, Koc A, et al. Treatment of chronic ear disease. Topical ciprofloxacin vs topical gentamicin. Arch Otolaryngol Head Neck Surg. Dec. 1995;121(12):1414-6. [pmid: 7488373].
173 Valtonen H, Tuomilehto H, Qvarnberg Y, et al. A 14-year prospective follow-up study of children treated early in life with tympanostomy tubes: Part 2: Hearing outcomes. Arch Otolaryngol Head Neck Surg. Apr. 2005;131(4):299-303. [pmid: 15837896].
174 Valtonen HJ, Qvarnberg YH, Nuutinen J. Otological and audiological outcomes five years after tympanostomy in early childhood. Laryngoscope. Apr. 2002;112(4):669-75. [pmid: 12150521].
175 van den Aardweg MT, Schilder AG, Herkert E, et al. Adenoidectomy for recurrent or chronic nasal symptoms in children. Cochrane Database Syst Rev. 2010;(1):CD008282. [pmid: 20091663].
176 van der Veen EL, Rovers MM, Albers FW, et al. Effectiveness of trimethoprim/sulfamethoxazole for children with chronic active otitis media: a randomized, placebo-controlled trial. Pediatrics. May. 2007;119(5):897-904. [pmid: 17473089].
177 van der Veen EL, Schilder AG, Timmers TK, et al. Effect of long-term trimethoprim/sulfamethoxazole treatment on resistance and integron prevalence in the intestinal flora: a randomized, double-blind, placebo-controlled trial in children. J Antimicrob Chemother. May. 2009;63(5):1011-6. [pmid: 19297377].
178 van der Veen EL, Schilder AG, van Heerbeek N, et al. Predictors of chronic suppurative otitis media in children. Arch Otolaryngol Head Neck Surg. Oct. 2006;132(10):1115-8. [pmid: 17043261].
179 Vautel JM, Cauquil J, Perruchet AM, et al. Prevention of recurrent ear, nose, and throat infections in young children with Ribomunyl (R) double-blind, placebo-controlled study. Curr Ther Res Clin Exp. 1993:722-9.
180 Wahl RA, Aldous MB, Worden KA, et al. Echinacea purpurea and osteopathic manipulative treatment in children with recurrent otitis media: a randomized controlled trial. BMC Complement Altern Med. 2008;8:56. [pmid: 18831749].
181 Walker P. Ventilation tube duration versus site of placement. Aust N Z J Surg. Aug. 1997;67(8):571-2. [pmid: 9287928].
182 Wallace HC, Newbegin CJ. Does ENT outpatient review at 1-week post ventilation tube insertion improve outcome at 1 month in paediatric patients?. Clin Otolaryngol Allied Sci. Dec. 2004;29(6):595-7. [pmid: 15533143].
183 Watcha MF, Ramirez-Ruiz M, White PF, et al. Perioperative effects of oral ketorolac and acetaminophen in children undergoing bilateral myringotomy. Can J Anaesth. Sep. 1992;39(7):649-54. [pmid: 1394752].
184 Webb BD, Chang CY. Efficacy of tympanoplasty without mastoidectomy for chronic suppurative otitis media. Arch Otolaryngol Head Neck Surg. Nov. 2008;134(11):1155-8. [pmid: 19015443].
185 Weigel MT, Parker MY, Goldsmith MM, et al. A prospective randomized study of four commonly used tympanostomy tubes. Laryngoscope. Mar. 1989;99(3):252-6. [pmid: 2645490].
186 Welling DB, Forrest LA, Goll F 3rd. Safety of ototopical antibiotics. Laryngoscope. May. 1995;105(5 Pt 1):472-4. [pmid: 7760659].
187 Wright A, Hawkins CH, Anggård EE, et al. A controlled clinical trial of a therapeutic bacteriophage preparation in chronic otitis due to antibiotic-resistant Pseudomonas aeruginosa; a preliminary report of efficacy. Clinical otolaryngology : official journal of ENT-UK ; official journal of Netherlands Society for Oto-Rhino-Laryngology & Cervico-Facial Surgery. 2009:349-57.
188 Wustrow TP. Alternative versus conventional treatment strategy in uncomplicated acute otitis media in children: a prospective, open, controlled parallel-group comparison. Int J Clin Pharmacol Ther. Feb. 2004;42(2):110-9. [pmid: 15180172].
189 Xu YD, Ou YK, Zheng YQ, et al. The treatment for postirradiation otitis media with effusion: a study of three methods. Laryngoscope. Nov. 2008;118(11):2040-3. [pmid: 18818551].
190 Yuen PW, Lau SK, Chau PY, et al. Ofloxacin eardrop treatment for active chronic suppurative otitis media: prospective randomized study. Am J Otol. Sep. 1994;15(5):670-3. [pmid: 8572070].
191 Yung M, Smith P. Titanium versus nontitanium ossicular prostheses-a randomized controlled study of the medium-term outcome. Otol Neurotol. Jul. 2010;31(5):752-8. [pmid: 20502377].
192 Yung M, Vivekanandan S, Smith P. Randomized study comparing fascia and cartilage grafts in myringoplasty. Ann Otol Rhinol Laryngol. Aug. 2011;120(8):535-41. [pmid: 21922978].
193 Zanetti D, Nassif N, Antonelli AR. Surgical repair of bone defects of the ear canal wall with flexible hydroxylapatite sheets: a pilot study. Otol Neurotol. Nov. 2001;22(6):745-53. [pmid: 11698790].

## Wrong Intervention

1 Abzug MJ. Meeting the challenge of antibiotic resistance: an evidence-based approach to treatment. Pediatr Ann. Jul. 1999;28(7):460-7. [pmid: 10884857].
2 Banerjee AR, Jennings C, Marshall JN, et al. The effect of topical adrenaline on the development of myringosclerosis after tympanostomy tube insertion. Am J Otol. Jul. 2000;21(4):482-4. [pmid: 10912691].
3 Bernard PA, Stenstrom RJ, Feldman W, et al. Randomized, controlled trial comparing long-term sulfonamide therapy to ventilation tubes for otitis media with effusion. Pediatrics. Aug. 1991;88(2):215-22. [pmid: 1861917].
4 Bluestone CD. Pathogenesis of otitis media: role of eustachian tube. Pediatr Infect Dis J. Apr. 1996;15(4):281-91. [pmid: 8866795].
5 Boyd NH, Gottschall JA. Assessing the efficacy of tragal pumping: a randomized controlled trial. Otolaryngol Head Neck Surg. Jun. 2011;144(6):891-3. [pmid: 21493326].
6 Browning GG, Gatehouse S, Calder IT. Medical management of active chronic otitis media: a controlled study. J Laryngol Otol. Jun. 1988;102(6):491-5. [pmid: 3294318].
7 Browning GG, Picozzi G, Sweeney G, et al. Role of anaerobes in chronic otitis media. Clin Otolaryngol Allied Sci. Feb. 1983;8(1):47-51. [pmid: 6831755].
8 Buckley G, Hinton A. Otitis media with effusion in children shows a progressive resolution with time. Clin Otolaryngol Allied Sci. 1991;16(4):354-7. [pmid: 1934548].
9 Burke P. Otitis media--antibiotics or not?. Practitioner. Apr. 1992;236(1513):432-9. [pmid: 1454707].
10 Cantekin EI, McGuire TW, Griffith TL. Antimicrobial therapy for otitis media with effusion ('secretory' otitis media). JAMA. Dec. 18. 1991;266(23):3309-17. [pmid: 1683673].
11 Casselbrant ML, Doyle WJ, Honjo I, et al. Recent advances in otitis media. Eustachian tube and middle ear physiology and pathophysiology. Ann Otol Rhinol Laryngol Suppl. Apr. 1989;139:14-8. [pmid: 2494925].
12 Casselbrant ML, Mandel EM, Seroky JT, et al. A pilot study of the ability of the forced response test to discriminate between 3-year-old children with chronic otitis media with effusion or with recurrent acute otitis media. Acta Otolaryngol. Nov. 2011;131(11):1150-4. [pmid: 21846295].
13 Chan KH, Bluestone CD. Lack of efficacy of middle-ear inflation: treatment of otitis media with effusion in children. Otolaryngol Head Neck Surg. Apr. 1989;100(4):317-23. [pmid: 2498820].
14 Chen YW, Philip Chen KT, Chang PH, et al. Is otitis media with effusion almost always accompanying cleft palate in children?: The experience of 319 Asian patients. Laryngoscope. 2012;122(1):220-4. [pmid: 22183637].
15 Collins MP, Church MK. The effect of an anti-allergic, nasal decongestant combination ('Dimotapp') and sodium cromoglycate nose drops on the histamine content of adenoids, middle ear fluid and nasopharyngeal secretions of children with secretory otitis media. Curr Med Res Opin. 1983;8(6):392-4. [pmid: 6406156].
16 Combs JT. The effect of montelukast sodium on the duration of effusion of otitis media. Clin Pediatr (Phila). Jul–Aug. 2004;43(6):529-33. [pmid: 15248005].
17 Compliment JM, Gendelman MS, Allera JF, et al. Outpatient treatment suite: A safe and cost-effective venue to perform myringotomy and tubes placement in children. Int J Pediatr Otorhinolaryngol. 2003;67(11):1159-68. [pmid: 14597365].
18 Coulson CJ, Drake-Lee AB, Plant T, et al. Total serum IgE and IgE antibodies specific to house dust mite found in two aged-matched cohorts of children with and without otitis media with effusion. Clin Otolaryngol. Apr. 2006;31(2):130-3. [pmid: 16620332].
19 Dakin H, Petrou S, Haggard M, et al. Mapping analyses to estimate health utilities based on responses to the OM8-30 Otitis Media Questionnaire. Qual Life Res. Feb. 2010;19(1):65-80. [pmid: 19941078].
20 Daly K, Giebink GS, Batalden PB, et al. Resolution of otitis media with effusion with the use of a stepped treatment regimen of trimethoprim-sulfamethoxazole and prednisone. Pediatr Infect Dis J. Jul. 1991;10(7):500-6. [pmid: 1876465].
21 Daly KA, Hunter LL, Levine SC, et al. Relationships between otitis media sequelae and age. Laryngoscope. Sep. 1998;108(9):1306-10. [pmid: 9738746].
22 De Wals P, Petit G, Erickson LJ, et al. Benefits and costs of immunization of children with pneumococcal conjugate vaccine in Canada (Structured abstract). Vaccine. 2003:3757-64. [pmid: 12922109].
23 Dhillon RS. The middle ear in cleft palate children pre and post palatal closure. J R Soc Med. Dec. 1988;81(12):710-3. [pmid: 3065499].
24 Donaldson JD, Martin GF, Maltby CC, et al. The efficacy of pulse-dosed antibiotic therapy in the management of persistent otitis media with effusion. J Otolaryngol. Jun. 1990;19(3):175-8. [pmid: 2192073].
25 Edstrom S, Lundin K, Jeppsson PH. Secretory otitis media. Aspects on treatment and control. ORL J Otorhinolaryngol Relat Spec. 1977;39(2):68-73. [pmid: 333341].
26 Egeli E, Kiris M. Is aspiration necessary before tympanostomy tube insertion?. Laryngoscope. Mar. 1998;108(3):443-4. [pmid: 9504622].
27 File TM Jr, Hadley JA. Rational use of antibiotics to treat respiratory tract infections. Am J Manag Care. Aug. 2002;8(8):713-27. [pmid: 12212759].
28 Giebink GS, Daly K, Buran DJ, et al. Predictors for postoperative otorrhea following tympanostomy tube insertion. Arch Otolaryngol Head Neck Surg. May. 1992;118(5):491-4. [pmid: 1571119].
29 Gross RD, Burgess LP, Holtel MR, et al. Saline irrigation in the prevention of otorrhea after tympanostomy tube placement. Laryngoscope. Feb. 2000;110(2 Pt 1):246-9. [pmid: 10680924].
30 Gultekin E, Develioglu ON, Yener M, et al. Prevalence and risk factors for persistent otitis media with effusion in primary school children in Istanbul, Turkey. Auris Nasus Larynx. Apr. 2010;37(2):145-9. [pmid: 19541437].
31 Gurr A, Stark T, Pearson M, et al. The ciliary beat frequency of middle ear mucosa in children with chronic secretory otitis media. Eur Arch Otorhinolaryngol. Dec. 2009;266(12):1865-70. [pmid: 19387677].
32 Hall JW 3rd, Grose JH, Dev MB, et al. The effect of otitis media with effusion on complex masking tasks in children. Arch Otolaryngol Head Neck Surg. Aug. 1998;124(8):892-6. [pmid: 9708715].
33 Hartman M, Rovers MM, Ingels K, et al. Economic evaluation of ventilation tubes in otitis media with effusion. Arch Otolaryngol Head Neck Surg. Dec. 2001;127(12):1471-6. [pmid: 11735817].
34 Haugeto OK, Schroder KE, Mair IW. Secretory otitis media, oral decongestant and antihistamine. J Otolaryngol. Oct. 1981;10(5):359-62. [pmid: 7199092].
35 Healy GB. Antimicrobial therapy of chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. Oct. 1984;8(1):13-7. [pmid: 6389394].
36 Hester TO, Jones RO. Prophylactic antibiotics in surgery for chronic ear disease. Laryngoscope. Sep. 1998;108(9):1334-7. [pmid: 9738752].
37 Hester TO, Jones RO, Archer SM, et al. Prophylactic antibiotic drops after tympanostomy tube placement. Arch Otolaryngol Head Neck Surg. Apr. 1995;121(4):445-8. [pmid: 7702820].
38 Iwano T, Ushiro K, Yukawa N, et al. Active opening function of the human eustachian tube: comparison between sonotubometry and pressure equilibration test. Acta Otolaryngol Suppl. 1993;500:62-5. [pmid: 8452023].
39 Jensen JH, Leth N, Bonding P. Topical application of decongestant in dysfunction of the Eustachian tube: a randomized, double-blind, placebo-controlled trial. Clinical Otolaryngology and Allied Sciences. 1990:197-201. [pmid: 1697515].
40 Khan JA, Marcus P, Cummings SW. S-carboxymethylcysteine in otitis media with effusion. (A double-blind study). The Journal of laryngology and otology. 1981:995-1001. [pmid: 7028897].
41 Khanna V, Chander J, Nagarkar NM, et al. Clinicomicrobiologic evaluation of active tubotympanic type chronic suppurative otitis media. J Otolaryngol. Jun. 2000;29(3):148-53. [pmid: 10883827].
42 Kirglu M, Yildirim I, Aydogan B, et al. Autoimmunity in the etiology of otitis media with effusion. American Journal of Otolaryngology - Head and Neck Medicine and Surgery. 2003;24(3):159-62.
43 Kujawski OB, Poe DS. Laser eustachian tuboplasty. Otol Neurotol. Jan. 2004;25(1):1-8. [pmid: 14724483].
44 Kumar M, Maheshwar A, Mahendran S, et al. Could the presence of a Carhart notch predict the presence of glue at myringotomy?. Clinical Otolaryngology and Allied Sciences. 2003;28(3):183-6. [pmid: 12755752].
45 Leach AJ, Morris PS, Mathews JD. Compared to placebo, long-term antibiotics resolve otitis media with effusion (OME) and prevent acute otitis media with perforation (AOMwiP) in a high-risk population: a randomized controlled trial. BMC Pediatr. 2008;8:23. [pmid: 18513453].
46 Leonetti JP, Kircher ML, Jaber JJ, et al. Inner ear effects of canal wall down mastoidectomy. Otolaryngol Head Neck Surg. Apr. 2012;146(4):621-6. [pmid: 22203686].
47 Leonetti JP, Stankiewicz JA. Antimicrobial prophylaxis for recurrent otitis media. Otolaryngol Head Neck Surg. Jul. 1988;99(1):81-2. [pmid: 3140190].
48 Lesser TH, Clayton MI, Skinner D. Efficacy of medical treatment as an adjunct to surgery in the treatment of secretory otitis media. J Laryngol Otol. Dec. 1986;100(12):1347-50. [pmid: 3543180].
49 Lesser THJ, Clayton MI, Skinner D. Efficacy of medical treatment as an adjunct to surgery in the treatment of secretory otitis media. J Laryngol Otol. 1986;100(12):1347-50. [pmid: 3543180].
50 Maheshwar AA, Milling MA, Kumar M, et al. Use of hearing aids in the management of children with cleft palate. Int J Pediatr Otorhinolaryngol. Oct. 21. 2002;66(1):55-62. [pmid: 12363423].
51 Mandel EM, Casselbrant ML, Kurs-Lasky M, et al. Efficacy of ceftibuten compared with amoxicillin for otitis media with effusion in infants and children. The Pediatric infectious disease journal. 1996:409-14. [pmid: 8724062].
52 Mandel EM, Rockette HE, Bluestone CD, et al. Efficacy of amoxicillin with and without decongestant-antihistamine for otitis media with effusion in children. Results of a double-blind, randomized trial. N Engl J Med. Feb. 19. 1987;316(8):432-7. [pmid: 2880294].
53 Marchisio P, Principi N, Passali D, et al. Epidemiology and treatment of otitis media with effusion in children in the first year of primary school. Acta Otolaryngol. Jul. 1998;118(4):557-62. [pmid: 9726683].
54 Maw AR, Bawden R. Factors affecting resolution of otitis media with effusion in children. Clin Otolaryngol Allied Sci. Apr. 1994;19(2):125-30. [pmid: 8026089].
55 Maw AR, Parker AJ, Lance GN, et al. The effect of parental smoking on outcome after treatment for glue ear in children. Clin Otolaryngol Allied Sci. Oct. 1992;17(5):411-4. [pmid: 1458623].
56 Mawson SR, Adlington P, Evans M. A controlled study evaluation of adeno-tonsillectomy in children. J Laryngol Otol. 1967:777-90. [pmid: 5339527].
57 Mills R, Uttley A, McIntyre M. Relationship between acute suppurative otitis media and chronic secretory otitis media: role of antibiotics. J R Soc Med. Sep. 1984;77(9):754-7. [pmid: 6332914].
58 Moller P, Dingsor G. Otitis media with effusion: can erythromycin reduce the need for ventilating tubes?. J Laryngol Otol. Mar. 1990;104(3):200-2. [pmid: 2341774].
59 Motamed M, Thorne S, Narula A. Treatment of otitis media with effusion in children with mucopolysaccharidoses. Int J Pediatr Otorhinolaryngol. Jun. 30. 2000;53(2):121-4. [pmid: 10906517].
60 Mui S, Rasgon BM, Hilsinger RL Jr, et al. Tympanostomy tubes for otitis media: Quality-of-life improvement for children and parents. Ear, Nose and Throat Journal. 2005;84(7):418-24.
61 Nichani J, Camilleri AE, Broomfield S, et al. Optimizing local anesthesia for grommet insertion: eutectic mixture of local anaesthetics versus Ametop: a randomized clinical trial. Otol Neurotol. Aug. 2008;29(5):658-60. [pmid: 18665031].
62 Ojala K, Sorri M. Late post-operative hearing results correlated with the severity of tissue changes in ears with chronic otitis media. J Laryngol Otol. Feb. 1983;97(2):131-9. [pmid: 6827180].
63 Orlin MN, Effgen SK, Handler SD. Effect of otitis media with effusion on gross motor ability in preschool-aged children: preliminary findings. Pediatrics. Mar. 1997;99(3):334-7. [pmid: 9041283].
64 O'Shea JS, Langenbrunner DJ, McCloskey DE, et al. Diagnostic and therapeutic studies in childhood serous otitis media. Results of treatment with an antihistamine-adrenergic combination. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):285-9. [pmid: 6778329].
65 O'Shea JS, Langenbrunner DJ, McCloskey DE, et al. Childhood serous otitis media: fifteen months' observations of children untreated compared with those receiving an antihistamine-adrenergic combination. Clin Pediatr (Phila). Mar. 1982;21(3):150-3. [pmid: 7035052].
66 Otten FW, Grote JJ. Otitis media with effusion and chronic upper respiratory tract infection in children: a randomized, placebo-controlled clinical study. Laryngoscope. Jun. 1990;100(6):627-33. [pmid: 1693411].
67 Ozmen OA, Genc A, Ozmen S, et al. Successive medical treatment versus watchful waiting in chronic otitis media with effusion. Journal of International Advanced Otology. 2010:11-7.
68 Paradise JL, Dollaghan CA, Campbell TF, et al. Language, speech sound production, and cognition in three-year-old children in relation to otitis media in their first three years of life. Pediatrics. May. 2000;105(5):1119-30. [pmid: 10790473].
69 Persico M, Podoshin L, Fradis M. Otitis media with effusion: a steroid and antibiotic therapeutic trial before surgery. Ann Otol Rhinol Laryngol. 1978:191-5. [pmid: 646286].
70 Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl. 1992;83:22-5. [pmid: 1336892].
71 Pestieau SR, Quezado ZMN, Johnson YJ, et al. The effect of dexmedetomidine during myringotomy and pressure-equalizing tube placement in children. Paediatr Anaesth. 2011;21(11):1128-35. [pmid: 21575102].
72 Poe DS, Grimmer JF, Metson R. Laser eustachian tuboplasty: two-year results. Laryngoscope. Feb. 2007;117(2):231-7. [pmid: 17277615].
73 Potsic WP, Cohen M, Randall P, et al. A retrospective study of hearing impairment in three groups of cleft palate patients. Cleft Palate J. Jan. 1979;16(1):56-8. [pmid: 282030].
74 Rosenfeld RM. Nonsurgical management of surgical otitis media with effusion. J Laryngol Otol. Sep. 1995;109(9):811-6. [pmid: 7494110].
75 Rosenfeld RM, Post JC. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. Apr. 1992;106(4):378-86. [pmid: 1533027].
76 Roydhouse N. A controlled study of adenotonsillectomy. Archives of otolaryngology (Chicago, Ill. 1960;1970:611-6.
77 Roydhouse N. Antibiotic treatment of otitis media with effusion. N Z Med J. Sep. 11. 1991;104(919):380-2. [pmid: 1923078].
78 Safak MA, Kilic R, Haberal I, et al. A comparative study of azithromycin and pseudoephedrine hydrochloride for otitis media with effusion in children. Acta Otolaryngol. Dec. 2001;121(8):925-9. [pmid: 11813896].
79 Schilder AG, Hak E, Straatman H, et al. Long-term effects of ventilation tubes for persistent otitis media with effusion in children. Clin Otolaryngol Allied Sci. Oct. 1997;22(5):423-9. [pmid: 9372253].
80 Shinkwin CA, Murty GE, Simo R, et al. Per-operative antibiotic/steroid prophylaxis of tympanostomy tube otorrhoea: chemical or mechanical effect?. J Laryngol Otol. Jun. 1996;110(6):531-3. [pmid: 8763370].
81 Simons FE. Evolution of H1-receptor antagonist treatment. Ann Allergy. Sep. 1993;71(3):282-7. [pmid: 8103973].
82 Sorri M, Sipila P, Palva A, et al. Can secretory otitis media be prevented by oral decongestants?. Acta Oto-Laryngol. 1982:115-6.
83 Strachan DP, Cook DG. Health effects of passive smoking. 4. Parental smoking, middle ear disease and adenotonsillectomy in children. Thorax. Jan. 1998;53(1):50-6. [pmid: 9577522].
84 Sundberg L. Antibiotic treatment of secretory otitis media. Acta Otolaryngol Suppl (Stockh). 1984:26-9. [pmid: 6388231].
85 Sundberg L, Cederberg A, Eden T, et al. The effect of erythromycin on the nasopharyngeal pathogens in children with secretory otitis media. Acta Otolaryngol. Mar–Apr. 1984;97(3–4):379-83. [pmid: 6609521].
86 Takahashi H, Naito Y, Fujiki N, et al. Cochlear implant surgery in ears with chronic otitis media. Adv Otorhinolaryngol. 2000;57:93-5. [pmid: 11892226].
87 Thomsen J, Sederberg-Olsen J, Balle V, et al. Antibiotic treatment of children with secretory otitis media. Amoxicillin-clavulanate is superior to penicillin V in a double-blind randomized study. Arch Otolaryngol Head Neck Surg. Jul. 1997;123(7):695-9. [pmid: 9236587].
88 Thomsen J, Sederberg-Olsen J, Balle V, et al. Antibiotic treatment of children with secretory otitis media. A randomized, double-blind, placebo-controlled study. Arch Otolaryngol Head Neck Surg. Apr. 1989;115(4):447-51. [pmid: 2647105].
89 Thomsen J, Sederberg-Olsen J, Stangerup SE, et al. Long-term antibiotic treatment of children with secretory otitis media: a double-blind placebo-controlled study. Acta Otolaryngol Suppl. 1988;449:49-50. [pmid: 3059752].
90 Thoroddsen E. Measuring antibiotic levels in otitis media. Ear Nose Throat J. Jun. 1998;77(6 Suppl):13-5. [pmid: 9674329].
91 Toscani M, Drehobl M, Freed J, et al. A multicenter, randomized, comparative assessment in healthy pediatric volunteers of the palatability of oral antibiotics effective in the therapy of otitis media. Curr Ther Res Clin Exp. 2000:278-85.
92 van Balen FA, de Melker RA, Touw-Otten FW. Double-blind randomised trial of co-amoxiclav versus placebo for persistent otitis media with effusion in general practice. Lancet. Sep. 14. 1996;348(9029):713-6. [pmid: 8806290].
93 van der Merwe J, Wagenfeld DJ. The negative effects of mucolytics in otitis media with effusion. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde. 1987:625-6. [pmid: 3317935].
94 van Heerbeek N, Straetemans M, Wiertsema SP, et al. Effect of combined pneumococcal conjugate and polysaccharide vaccination on recurrent otitis media with effusion. Pediatrics. Mar. 2006;117(3):603-8. [pmid: 16510637].
95 Williams RL, Chalmers TC, Stange KC, et al. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion. A meta-analytic attempt to resolve the brouhaha. JAMA. Sep. 15. 1993;270(11):1344-51. [pmid: 8141875].
96 Yilmaz T, Kocan EG, Besler HT, et al. The role of oxidants and antioxidants in otitis media with effusion in children. Otolaryngol Head Neck Surg. Dec. 2004;131(6):797-803. [pmid: 15577771].
97 Yu MS, Kim HC, Ahn JH. Management and outcomes of chronic otitis media in patients who received solid organ transplantation. Otolaryngol Head Neck Surg. Apr. 2012;146(4):567-71. [pmid: 22217912].
98 Zielhuis GA, Rach GH, van den Broek P. Screening for otitis media with effusion in preschool children. Lancet. Feb. 11. 1989;1(8633):311-4. [pmid: 2563465].

## Wrong Comparison

1 Speech reception in noise: an indicator of benefit from otitis media with effusion surgery. Clin Otolaryngol Allied Sci. Oct. 2004;29(5):497-504. [pmid: 15373863].
2 Ahmad Rohail ZIG, Hussain Butt Mohammad Riaz Shahid Imran Ali Iqbal. A comparison of medical treatment versus surgical treatment for the management of Otitis media with effusion. Ann King Edward Med Uni. 2006;12(1):64-7.
3 Arcand P, Gauthier P, Bilodeau G, et al. Post-myringotomy care: a prospective study. J Otolaryngol. Oct. 1984;13(5):305-8. [pmid: 6085804].
4 Arick DS, Silman S. Treatment of otitis media with effusion based on politzerization with an automated device. Ear Nose Throat J. Apr. 2000;79(4):290-2. 4, 6 passim. [pmid: 10786393].
5 Bayramoglu I, Ardic FN, Kara CO, et al. Importance of mastoid pneumatization on secretory otitis media. Int J Pediatr Otorhinolaryngol. May. 4. 1997;40(1):61-6. [pmid: 9184979].
6 Berman S, Grose K, Zerbe GO. Medical management of chronic middle-ear effusion. Results of a clinical trial of prednisone combined with sulfamethoxazole and trimethoprim. Am J Dis Child. Jun. 1987;141(6):690-4. [pmid: 3554985].
7 Bonding P, Lorenzen E. Chronic secretory otitis media--long-term results after treatment with grommets. ORL J Otorhinolaryngol Relat Spec. 1974;36(4):227-35. [pmid: 4215997].
8 Bower C, Waner M. Laser assisted myringotomy. Current Opinion in Otolaryngology and Head and Neck Surgery. 1999;7(6):335-8.
9 Brooks DN, Dogra TS. Long term results of treatment of middle ear effusion. J Laryngol Otol. Oct. 1980;94(10):1107-15. [pmid: 7430772].
10 Cannon CR. Early otorrhea following ear tube insertion. J Miss State Med Assoc. Feb. 1997;38(2):39-43. [pmid: 9048472].
11 Chang CW, Yang YW, Fu CY, et al. Differences between children and adults with otitis media with effusion treated with CO2 laser myringotomy. Journal of the Chinese Medical Association. 2011.
12 Cohen D, Shechter Y, Slatkine M, et al. Laser myringotomy in different age groups. Arch Otolaryngol Head Neck Surg. 2001;127(3):260-4. [pmid: 11255469].
13 Cohen MS, Mandel EM, Furman JM, et al. Tympanostomy tube placement and vestibular function in children. Otolaryngol Head Neck Surg. Oct. 2011;145(4):666-72. [pmid: 21676943].
14 Cook SP, Brodsky L, Reilly JS, et al. Effectiveness of adenoidectomy and laser tympanic membrane fenestration. Laryngoscope. Feb. 2001;111(2):251-4. [pmid: 11210870].
15 Cotter CS, Kosko JR. Effectiveness of laser-assisted myringotomy for otitis media in children. Laryngoscope. Mar. 2004;114(3):486-9. [pmid: 15091222].
16 Cowan DL, Brown MJ. Seromucinous otitis media and its sequelae. (A retrospective study of 242 children). J Laryngol Otol. Dec. 1974;88(12):1237-47. [pmid: 4452807].
17 Crowther JA, Simpson D. Medical treatment of chronic otitis media: steroid or antibiotic with steroid ear-drops?. Clin Otolaryngol Allied Sci. Apr. 1991;16(2):142-4. [pmid: 2070529].
18 Daly KA, Giebink GS, Lindgren B, et al. Randomized trial of the efficacy of trimethoprim-sulfamethoxazole and prednisone in preventing post-tympanostomy tube morbidity. Pediatr Infect Dis J. Dec. 1995;14(12):1068-74. [pmid: 8745020].
19 Deutsch ES, Cook SP, Shaha S, et al. Duration of patency of laser-assisted tympanic membrane fenestration. Arch Otolaryngol Head Neck Surg. Aug. 2003;129(8):825-8. [pmid: 12925339].
20 Diacova S, McDonald TJ. A comparison of outcomes following tympanostomy tube placement or conservative measures for management of otitis media with effusion. Ear Nose Throat J. Sep. 2007;86(9):552-4. [pmid: 17970145].
21 Dragicevic D, Vlaski L, Komazec Z, et al. Transient evoked otoacoustic emissions in young children with otitis media with effusion before and after surgery. Auris Nasus Larynx. 2010;37(3):281-5. [pmid: 19864093].
22 Fior R, Veljak C. Late results and complications of tympanostomy tube insertion for prophylaxis of recurrent purulent otitis media in pediatric age. Int J Pediatr Otorhinolaryngol. Dec. 1984;8(2):139-46. [pmid: 6526581].
23 Franklin JH, Marck PA. Outcome analysis of children receiving tympanostomy tubes. J Otolaryngol. Oct. 1998;27(5):293-7. [pmid: 9800629].
24 Friedman O, Deutsch ES, Reilly JS, et al. The feasibility of office-based laser-assisted tympanic membrane fenestration with tympanostomy tube insertion: the duPont Hospital experience. Int J Pediatr Otorhinolaryngol. Jan. 11. 2002;62(1):31-5. [pmid: 11738691].
25 Gaihede M, Lildholdt T, Lunding J. Sequelae of secretory otitis media: changes in middle ear biomechanics. Acta Otolaryngol. May. 1997;117(3):382-9. [pmid: 9199524].
26 Garin P, Ledeghen S, Van Prooyen-Keyser S, et al. Office-based CO2 laser-assisted tympanic membrane fenestration addressing otitis media with effusion. J Clin Laser Med Surg. Aug. 2001;19(4):185-7. [pmid: 11523861].
27 Gates GA, Wachtendorf C, Hearne EM, et al. Treatment of chronic otitis media with effusion: results of myringotomy. Auris Nasus Larynx. Suppl 1. 1985;12:S262-4. [pmid: 3915205].
28 Gebhart DE. Tympanostomy tubes in the otitis media prone child. Laryngoscope. Jun. 1981;91(6):849-66. [pmid: 7017311].
29 Gorur K, Ozcan C, Talas DU. The computed tomographical and tympanometrical evaluation of mastoid pneumatization and attic blockage in patients with chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. Mar. 2006;70(3):481-5. [pmid: 16165223].
30 Gottschalk GH. Serous otitis. A conservative approach to treatment. Arch Otolaryngol. Aug. 1972;96(2):110-2. [pmid: 5081913].
31 Gundersen T, Tonning FM. Ventilating tubes in the middle ear. Arch Otolaryngol. Apr. 1976;102(4):198-9. [pmid: 1267702].
32 Gundersen T, Tonning FM, Kveberg KH. Ventilating tubes in the middle ear. Long-term observations. Arch Otolaryngol. Dec. 1984;110(12):783-4. [pmid: 6542349].
33 Haberkamp TJ, Silverstein HL. Permanent middle ear aeration: long-term follow-up of transosseous ventilating tubes. Laryngoscope. Oct. 1987;97(10):1145-8. [pmid: 3657360].
34 Harrison H, Fixsen A, Vickers A. A randomized comparison of homoeopathic and standard care for the treatment of glue ear in children. Complement Ther Med. Sep. 1999;7(3):132-5. [pmid: 10581822].
35 Holt JJ, Harner SG. Effects of large-bore middle ear ventilation tubes. Otolaryngol Head Neck Surg. Sep–Oct. 1980;88(5):581-5. [pmid: 7192378].
36 Hunter LL, Margolis RH, Rykken JR, et al. High frequency hearing loss associated with otitis media. Ear Hear. Feb. 1996;17(1):1-11. [pmid: 8741962].
37 Hussl B, Welzl-Mueller K. Secretory otitis media and mastoid pneumatization. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):79-82. [pmid: 6778358].
38 Iino Y, Imamura Y, Harigai S, et al. Efficacy of tympanostomy tube insertion for otitis media with effusion in children with Down syndrome. Int J Pediatr Otorhinolaryngol. Aug. 5. 1999;49(2):143-9. [pmid: 10504021].
39 Kakigi A, Takeda T, Nakatani H, et al. Modification of surgical procedures of type 1 tympanoplasty for non-cholesteatomatous chronic otitis media. ORL J Otorhinolaryngol Relat Spec. Suppl 1. 2010;71:71-3. [pmid: 20185952].
40 Kalcioglu MT, Cokkeser Y, Kizilay A, et al. Follow-up of 366 ears after tympanostomy tube insertion: Why is it draining?. Otolaryngol Head Neck Surg. 2003;128(4):560-4. [pmid: 12707661].
41 Kawasaki Y, Sakamoto Y, Honmura Y, et al. Long-term results of ventilation tube for otitis media with effusion in children. Auris Nasus Larynx. Suppl 1. 1985;12:S225-7. [pmid: 3835916].
42 Kim DS, Moore PL, Rockley TJ. Long-term Paparella II grommet use in the management of persistent childhood otitis media: a 5-year follow-up study. Clin Otolaryngol Allied Sci. Oct. 2004;29(5):553-7. [pmid: 15373873].
43 Kobayashi H, Sakuma T, Yamada N, et al. Clinical outcomes of ventilation tube placement in children with cleft palate. Int J Pediatr Otorhinolaryngol. 2012;76(5):718-21. [pmid: 22386274].
44 Lau P, Shelton C, Goode RL. Heat myringotomy. Laryngoscope. Jan. 1985;95(1):38-42. [pmid: 3880850].
45 Lesser TH, Williams KR, Skinner DW. Tympanosclerosis, grommets and shear stresses. Clin Otolaryngol Allied Sci. Oct. 1988;13(5):375-80. [pmid: 3243014].
46 Lildholdt T, Kortholm B. Beclomethasone nasal spray in the treatment of middle-ear effusion - a double-blind study. Int J Pediatr Otorhinolaryngol. Jun. 1982;4(2):133-7. [pmid: 6752070].
47 Mair IW, Haugeto OK, Elverland HH, et al. Chronic secretory otitis media. Int J Pediatr Otorhinolaryngol. Jun. 1980;2(2):161-70. [pmid: 6892364].
48 Maw AR. Development of tympanosclerosis in children with otitis media with effusion and ventilation tubes. J Laryngol Otol. Aug. 1991;105(8):614-7. [pmid: 1919311].
49 Maw AR, Parker AJ. A model to refine the selection of children with otitis media with effusion for adenoidectomy. Clin Otolaryngol Allied Sci. Jun. 1993;18(3):164-70. [pmid: 8365001].
50 Mawson SR, Fagan P. Tympanic effusions in children. Long-term results of treatment by myringotomy, aspiration and indwelling tubes (grommets). J Laryngol Otol. Feb. 1972;86(2):105-19. [pmid: 5058477].
51 Mortensen EH, Lildholdt T. Ventilation tubes and cholesteatoma in children. J Laryngol Otol. Jan. 1984;98(1):27-9. [pmid: 6537964].
52 Muhammad Saeed MA. Secretory Otitis Media in adults. Pak J Otolaryngol. 2003;19(4):38-40.
53 Nurliza I, Lim LH. Retrospective review of grommet insertions for otitis media with effusion in children in Singapore. Med J Malaysia. Aug. 2011;66(3):227-30. [pmid: 22111445].
54 Ojala K, Sorri M. The preoperative state of infection in chronic otitis media correlated with postoperative hearing results. Arch Otorhinolaryngol. 1982;234(3):253-62. [pmid: 7115198].
55 Parikh A, Alles R, Hawk L, et al. Treatment of allergic rhinitis and its impact in children with chronic otitis media with effusion. Journal of Audiological Medicine. 2000:104-17.
56 Parker AJ, Maw AR. Treatment of glue ear in relation to radiographic palatal airway size: a predictor for outcome following adenoidectomy?. J Laryngol Otol. Jan. 1989;103(1):66-70. [pmid: 2646383].
57 Pereira MB, Pereira DR, Costa SS. Tympanostomy tube sequelae in children with otitis media with effusion: a three-year follow-up study. Braz J Otorhinolaryngol. Jul–Aug. 2005;71(4):415-20. [pmid: 16446953].
58 Peters SA, Grievink EH, van Bon WH, et al. The effects of early bilateral otitis media with effusion on educational attainment: a prospective cohort study. J Learn Disabil. Feb. 1994;27(2):111-21. [pmid: 8195687].
59 Plotkin RP. Middle ear ventilation with the Castelli membrane tube. Laryngoscope. Jul. 1981;91(7):1173-5. [pmid: 7195446].
60 Poetker DM, Ubell ML, Kerschner JE. Disease severity in patients referred to pediatric otolaryngologists with a diagnosis of otitis media. Int J Pediatr Otorhinolaryngol. Feb. 2006;70(2):311-7. [pmid: 16125250].
61 Ponduri S, Bradley R, Ellis PE, et al. The management of otitis media with early routine insertion of grommets in children with cleft palate -- a systematic review. Cleft Palate Craniofac J. Jan. 2009;46(1):30-8. [pmid: 19115800].
62 Prokopakis EP, Hajiioannou JK, Velegrakis GA, et al. The role of laser assisted tympanostomy (LAT) in treating allergic children with chronic serous otitis media. Int J Pediatr Otorhinolaryngol. Feb. 25. 2002;62(3):207-14. [pmid: 11852122].
63 Prokopakis EP, Lachanas VA, Christodoulou PN, et al. Laser-assisted tympanostomy in pediatric patients with serous otitis media. Otolaryngol Head Neck Surg. Oct. 2005;133(4):601-4. [pmid: 16213936].
64 Puhakka H, Haapaniemi J, Tuohimaa P, et al. Peroral prednisolone in the treatment of middle-ear effusion in children: a double-blind study. Auris Nasus Larynx. Suppl 1. 1985;12:S268-71. [pmid: 3915207].
65 Rakover Y, Keywan K, Rosen G. Comparison of the incidence of cholesteatoma surgery before and after using ventilation tubes for secretory otitis media. Int J Pediatr Otorhinolaryngol. Nov. 30. 2000;56(1):41-4. [pmid: 11074114].
66 Ramadan HH, Tarazi T, Zaytoun GM. Use of prophylactic otic drops after tympanostomy tube insertion. Arch Otolaryngol Head Neck Surg. May. 1991;117(5):537. [pmid: 2021473].
67 Rashid D, Ahmad B, Malik SM, et al. Otitis media with effusion-cost effective options. Journal of the College of Physicians and Surgeons Pakistan. 2002;12(5):274-6.
68 Reidpath DD, Glasziou PP, Del Mar C. Systematic review of autoinflation for treatment of glue ear in children. BMJ. May. 1. 1999;318(7192):1177. [pmid: 10221942].
69 Rotta Pereira MB, Ruttkay Pereira DR, Selaimen Da Costa S. Tympanostomy tube sequelae in children with otitis media with effusion: A three-year follow-up study. Revista Brasileira De Otorrinolaringologia. 2005;71(4):415-20. [pmid: 16446953].
70 Ryding M, White P, Kalm O. Course and long-term outcome of 'refractory' secretory otitis media. J Laryngol Otol. Feb. 2005;119(2):113-8. [pmid: 15829063].
71 Saleem Y, Ramachandran S, Ramamurthy L, et al. Role of otoacoustic emission in children with middle-ear effusion and grommets. J Laryngol Otol. Oct. 2007;121(10):943-6. [pmid: 17419898].
72 Schwartz RH. Otitis media with effusion: results of treatment with a short course of oral prednisone or intranasal beclomethasone aerosol. Otolaryngol Head Neck Surg. May–Jun. 1981;89(3 Pt 1):386-91. [pmid: 6791096].
73 Sedlmaier B, Jivanjee A, Gutzler R, et al. Ventilation time of the middle ear in otitis media with effusion (OME) after CO2 laser myringotomy. Laryngoscope. Apr. 2002;112(4):661-8. [pmid: 12150520].
74 Sedlmaier B, Jivanjee A, Jovanovic S. Transtympanic middle ear ventilation in otitis media with effusion (OME) after myringotomy with a CO2 laserotoscope. Medical Laser Application. 2002;17(3):214-22.
75 Silman S, Arick DS, Emmer MB. Nonsurgical home treatment of middle ear effusion and associated hearing loss in children. Part II: Validation study. Ear Nose Throat J. Oct. 2005;84(10):646. 8. 50 passim. [pmid: 16382747].
76 Sinha V, Patel BH, Sinha S. Incidence of uncomplained secretory otitis media in patients undergoing adenotonswlectomy. Indian Journal of Otolaryngology and Head and Neck Surgery. 2005;57(2):110-1. [pmid: 23120144].
77 Skovbjerg S, Roos K, Holm SE, et al. Spray bacteriotherapy decreases middle ear fluid in children with secretory otitis media. Arch Dis Child. Feb. 2009;94(2):92-8. [pmid: 18713796].
78 Stenstrom R, Pless IB, Bernard P. Hearing thresholds and tympanic membrane sequelae in children managed medically or surgically for otitis media with effusion. Arch Pediatr Adolesc Med. Dec. 2005;159(12):1151-6. [pmid: 16330739].
79 Tay HL, Mills RP. Predictive factors for the resolution of childhood otitis media with effusion following initial surgical treatment. Clin Otolaryngol Allied Sci. Oct. 1994;19(5):385-7. [pmid: 7834877].
80 Tay HL, Mills RP. The assessment of hearing results following surgery for otitis media with effusion using the Glasgow Benefit Plot. J Laryngol Otol. Sep. 1994;108(9):733-5. [pmid: 7964132].
81 Theoharides TC, Manolidis SS, Vliagoftis H, et al. Treatment of secretory otitis media with local instillation of hydroxyzine. Int Arch Allergy Immunol. 1994;103(1):95-101. [pmid: 8260856].
82 Timmerman AA, Anteunis LJ, Meesters CM. Response-shift bias and parent-reported quality of life in children with otitis media. Arch Otolaryngol Head Neck Surg. Sep. 2003;129(9):987-91. [pmid: 12975273].
83 To SS, Pahor AL, Robin PE. A prospective trial of unilateral grommets for bilateral secretory otitis media in children. Clin Otolaryngol Allied Sci. Apr. 1984;9(2):115-7. [pmid: 6380827].
84 Van Heerbeek N, De Saar GM, Mulder JJ. Long-term ventilation tubes: results of 726 insertions. Clin Otolaryngol Allied Sci. Oct. 2002;27(5):378-83. [pmid: 12383301].
85 Widemar L, Svensson C, Rynnel-Dagoo B, et al. The effect of adenoidectomy on secretory otitis media: a 2-year controlled prospective study. Clin Otolaryngol Allied Sci. Dec. 1985;10(6):345-50. [pmid: 3830481].
86 Witsell DL, Stewart MG, Monsell EM, et al. The Cooperative Outcomes Group for ENT: a multicenter prospective cohort study on the outcomes of tympanostomy tubes for children with otitis media. Otolaryngol Head Neck Surg. Feb. 2005;132(2):180-8. [pmid: 15692524].
87 Yaman H, Yilmaz S, Alkan N, et al. Shepard grommet tympanostomy tube complications in children with chronic otitis media with effusion. Eur Arch Otorhinolaryngol. Aug. 2010;267(8):1221-4. [pmid: 20204390].

## Same Data Appears in Another Included Article

1 Blanshard J, Maw A, Bawden R. The treatment of otitis media with effusion in children by autoinflation of the middle ear. 2nd European Congress of Oto-Rhino-Larynogology and cervico-facial surgery. 1992:31-7.
2 Browning GG. Watchful waiting in childhood otitis media with effusion. Clinical Otolaryngology and Allied Sciences. 2001;26(4):263-4. [pmid: 11559333].
3 Ingels K, Rovers MM, van der Wilt GJ, et al. Ventilation tubes in infants increase the risk of otorrhoea and antibiotic usage. B-ENT. 2005;1(4):173-6. [pmid: 16429748].
4 Jones NS, Haggard MP, Gannon MM, et al. Surgery for persistent otitis media with effusion: generalizability of results from the UK trial (TARGET). Trial of Alternative Regimens in Glue Ear Treatment. Clin Otolaryngol Allied Sci. Oct. 2001;26(5):417-24. [pmid: 11678951].
5 Maw AR. Chronic otitis media with effusion and adeno-tonsillectomy--a prospective randomized controlled study. Int J Pediatr Otorhinolaryngol. Dec. 1983;6(3):239-46. [pmid: 6373644].
6 Maw AR. Chronic otitis media with effusion (glue ear) and adenotonsillectomy: prospective randomised controlled study. Br Med J (Clin Res Ed). Nov. 26. 1983;287(6405):1586-8. [pmid: 6416513].
7 Maw AR. Factors affecting adenoidectomy for otitis media with effusion (glue ear). J R Soc Med. Dec. 1985;78(12):1014-8. [pmid: 4067973].
8 Maw AR. The long term effect of adenoidectomy on established otitis media with effusion in children. Auris Nasus Larynx. Suppl 1. 1985;12:S234-6. [pmid: 3835918].
9 Maw AR. Factors affecting adenoidectomy for otitis media with effusion (glue ear). J R Soc Med. 1985:1014-8. [pmid: 4067973].
10 Maw AR, Bawden R. The long term outcome of secretory otitis media in children and the effects of surgical treatment: a ten year study. Acta Otorhinolaryngol Belg. 1994;48(4):317-24. [pmid: 7810300].
11 Maw AR, Bawden R. Does adenoidectomy have an adjuvant effect on ventilation tube insertion and thus reduce the need for re-treatment?. Clin Otolaryngol Allied Sci. 1994:340-3. [pmid: 7994892].
12 MRC Group MOMS. The role of ventilation tube status in the hearing levels in children managed for bilateral persistent otitis media with effusion. Clin Otolaryngol Allied Sci. Apr. 2003;28(2):146-53. [pmid: 12680834].
13 Paradise JL, Dollaghan CA, Campbell TF, et al. Otitis media and tympanostomy tube insertion during the first three years of life: developmental outcomes at the age of four years. Pediatrics. Aug. 2003;112(2):265-77. [pmid: 12897272].
14 Paradise JL, Feldman HM, Campbell TF, et al. Early versus delayed insertion of tympanostomy tubes for persistent otitis media: developmental outcomes at the age of three years in relation to prerandomization illness patterns and hearing levels. Pediatr Infect Dis J. Apr. 2003;22(4):309-14. [pmid: 12690269].
15 Rovers MM, Straatman H, Ingels K, et al. The effect of short-term ventilation tubes versus watchful waiting on hearing in young children with persistent otitis media with effusion: a randomized trial. Ear Hear. Jun. 2001;22(3):191-9. [pmid: 11409855].
16 Slack RW, Maw AR, Capper JW, et al. Prospective study of tympanosclerosis developing after grommet insertion. J Laryngol Otol. Aug. 1984;98(8):771-4. [pmid: 6470572].
17 Stangerup S, Tos M. Autoinflation in the treatment of Eustachian tube dysfunction, secretory otitis media and its sequelae Recent advances in otitis media. Amsterdam/New York. Kugler Publications. 1994:759-63.