# Search Strategy

PubMed: Search Jan. 8, 2012

Search | Query | Items found
#1 | Search "Otitis Media with Effusion"[Mesh] | 4535
#2 | Search "Ear, Middle/secretion"[Mesh] | 101
#3 | Search "glue ear"[tiab] | 251
#4 | Search "otitis media"[tiab] | 15150
#5 | Search middle ear effusion* | 1609
#6 | Search (OME[tiab] OR SOM[tiab]) AND (otitis[tiab] OR ear*[tiab]) | 1463
#7 | Search "nonsuppurative otitis"[tiab] | 0
#8 | Search "serous otitis"[tiab] | 610
#9 | Search "secretory otitis"[tiab] | 940
#10 | Search "adhesive otitis"[tiab] | 165
#11 | Search "exudative otitis"[tiab] | 89
#12 | Search (mucoid*[tiab] AND otitis[tiab]) OR (mucous[tiab] AND otitis[tiab]) OR (sero-muco*[tiab] AND otitis[tiab]) OR (sero[tiab] OR muco[tiab] AND otitis[tiab]) OR (otitis[tiab] AND serosa[tiab]) | 412
#13 | Search (mucoid*[tiab] AND middle[tiab] AND ear*[tiab]) OR (mucous[tiab] AND middle[tiab] AND ear*[tiab]) OR (seromuc*[tiab] AND middle[tiab] AND ear*[tiab]) | 462
#14 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 17356
#15 | Search "Steroids"[Mesh] OR oral steroid* | 653912
#16 | Search nasal*[tiab] AND (topical steroid*[tiab]) | 213
#17 | Search "Anti-Bacterial Agents"[Mesh] OR antibiotic* | 367969
#18 | Search "ear popper"[tiab] OR manual therap*[tiab] | 965
#19 | Search autoinflation[tiab] | 49
#20 | Search pressure equalization tube*[tiab] | 58
#21 | Search "Adenoidectomy"[Mesh] OR adenoidectom*[tiab] | 3873
#22 | Search "Middle Ear Ventilation"[Mesh] OR tympanostomy[tiab] OR ((middle[tiab] AND (ear*[tiab] OR tympanic[tiab])) AND tube*[tiab]) | 4130
#23 | Search grommet*[tiab] | 445
#24 | Search ventilation tube*[tiab] | 777
#25 | Search "Tonsillectomy"[Mesh] OR tonsillectomy[tiab] | 8554
#26 | Search "Leukotriene Antagonists/therapeutic use"[Mesh] OR "Leukotriene Antagonists" [Pharmacological Action] | 4042
#27 | Search "Acetates/therapeutic use"[Mesh] | 2774
#28 | Search "Quinolines/therapeutic use"[Mesh] | 35055
#29 | Search "Combined Modality Therapy"[Mesh] OR combined modality therap*[tiab] | 177569
#30 | Search myringotomy[tiab] | 1061
#31 | Search "Otologic Surgical Procedures"[Mesh] | 13165
#32 | Search "Phosphorylcholine/administration and dosage"[Mesh] OR "Phosphorylcholine/therapeutic use"[Mesh] | 412
#33 | Search "Watchful Waiting"[Mesh] OR watchful waiting*[tiab] | 1517
#34 | Search tubulation[tiab] | 257
#35 | Search #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #31 or #32 or #33 or #34 | 1231827
#36 | Search #14 and #35 | 6961
#37 | Search #36 or #30 | 7507
#38 | Search #37 Limits: Humans | 6659
#39 | Search "Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH] | 398253
#40 | Search #38 and #39 | 602
#41 | Search #38 Limits: Controlled Clinical Trial | 70
#42 | Search #38 AND "Controlled Clinical Trials as Topic"[Mesh] | 134
#43 | Search #40 or #41 or #42 | 763
#44 | Search #38 AND systematic[sb] | 258
#45 | Search #38 Limits: Meta-Analysis | 55
#46 | Search #44 or #45 | 258
#47 | Search ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Epidemiologic Studies"[MeSH] OR "Cross-Sectional Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR "Seroepidemiologic Studies"[MeSH] OR "Multicenter Study"[Publication Type] OR “Multicenter Studies as Topic”[MeSH] OR "Evaluation Studies"[Publication Type] OR “Evaluation Studies as Topic”[MeSH]) | 2315890
#48 | Search #38 and #47 | 2603
#49 | Search #38 and harms | 5
#50 | Search #43 or #46 or #48 or #49 ALL STUDY TYPES GATHERED EXCEPT LIT REVIEWS, SAVED SEPARATELY. | 2939
#51 | Search #38 Limits: Review | 979
#52 | Search #51 not #46 THE LIT. REVIEWS. | 851

Cochrane Library: Search Jan. 8, 2012

ID | Search | Hits
#1 | [underlined: "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR ((sero OR muco) AND otitis) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AND ear*) OR (seromuc* AND middle AND ear*)] | 2221
#2 | [underlined: "Steroids" OR oral steroid* OR (nasal* AND topical steroid*) OR "Anti-Bacterial Agents" OR antibiotic* OR "ear popper" OR manual therap* OR pressure equalization tube* OR adenoidectom* OR "Middle Ear Ventilation" OR tympanostomy OR (middle AND ear*AND tube*) OR (middle AND tympanic* AND tube*) OR grommet* OR ventilation tube* OR tonsillectomy OR "Leukotriene Antagonists/therapeutic use" OR "Leukotriene Antagonists" OR acetate* OR quinolone* OR phosphorylcholine OR combined modality therap* OR "Otologic Surgical Procedures" OR watchful waiting* OR tabulation OR autoinflation] | 50759
#3 | [underlined: (#1 AND #2)] | 1023
#4 | [underlined: (#3 OR myringotomy)] | 1119
#5 | [underlined: "Randomized Controlled Trial" OR "Single-Blind Method" OR "Double-Blind Method" OR "Random Allocation" OR "Controlled Clinical Trial" OR "Controlled Clinical Trials as Topic" OR (control* AND trial)] | 689256
#6 | [underlined: (#4 AND #5)] | 1067
#7 | [underlined: ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Epidemiologic Studies"[MeSH] OR "Cross-Sectional Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR "Seroepidemiologic Studies"[MeSH] OR "Multicenter Study"[Publication Type] OR "Multicenter Studies as Topic"[MeSH] OR "Evaluation Studies"[Publication Type] OR "Evaluation Studies as Topic"[MeSH])] | 120400
#8 | [underlined: (#4 AND #7)] | 308
#9 | [underlined: (#4)] | 172
#10 | [underlined: (#6 OR #8 OR #9)] | 1119

Embase: Search Jan. 8, 2012

No. | Query | Results
#1 | 'otitis media with effusion'/exp OR 'otitis media with effusion' OR 'otitis media'/exp OR 'otitis media' OR 'middle ear secretion' OR 'ear, middle/secretion' OR 'glue ear'/exp OR 'glue ear' OR middle AND ('ear'/exp OR ear) AND effusion* OR ome OR som OR ('otitis'/exp OR otitis AND ('ear'/exp OR ear)) OR ('otitis'/exp OR otitis AND ears) OR 'nonsuppurative otitis' OR 'serous otitis'/exp OR 'serous otitis' OR 'secretory otitis' OR 'adhesive otitis' OR 'exudative otitis' OR (mucoid AND ('otitis'/exp OR otitis)) OR (mucous AND ('otitis'/exp OR otitis)) OR ('otitis'/exp OR otitis AND ('serosa'/exp OR serosa)) OR (mucoid AND middle AND ('ear'/exp OR ear)) OR (mucous AND middle AND ('ear'/exp OR ear)) AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) Bottom of Form Bottom of Form | 23,677
#2 | 'steroids'/exp OR steroids OR 'oral'/exp OR oral AND steroid* OR (nasal* AND ('topical'/exp OR topical) AND ('steroid'/exp OR steroid)) OR 'antibacterial agents' OR 'anti-bacterial agents' OR antibiotic* OR autoinflation OR 'ear popper' OR manual AND ('therapy'/exp OR therapy) OR 'pressure'/exp OR pressure AND equalization AND ('tube'/exp OR tube) OR 'adenoidectomy'/exp OR adenoidectomy OR 'middle ear ventilation'/exp OR 'middle ear ventilation' OR tympanostomy OR (middle AND ('ear'/exp OR ear) AND ('tube'/exp OR tube)) OR (middle AND tympanic* AND tube*) OR grommet* OR 'ventilation'/exp OR ventilation AND ('tube'/exp OR tube) OR 'tonsillectomy'/exp OR tonsillectomy OR 'leukotriene antagonists/therapeutic use' OR 'leukotriene antagonists'/exp OR 'acetate'/exp OR acetate OR quinolone* OR 'phosphorylcholine'/exp OR phosphorylcholine OR combined AND modality AND ('therapy'/exp OR therapy) OR 'otologic surgical procedures'/exp OR 'otologic surgical procedures' OR watchful AND waiting OR tubulation AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 1,730
#3 | #1 AND #2 | 96
#4 | 'myringotomy'/exp OR myringotomy AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 1,989
#5 | #3 OR #4 | 2,056
#6 | #5 AND [review]/lim | 264
#7 | 'randomized controlled trial'/exp OR 'single blind procedure'/exp OR 'double blind procedure'/exp OR 'random allocation' | 333,668
#8 | #5 AND #7 | 140
#9 | 'controlled clinical trial'/exp OR 'controlled clinical trial (topic)'/exp | 421,718
#10 | #5 AND #9 | 162
#11 | 'follow up'/exp | 602,436
#12 | #5 AND #11 | 194
#13 | 'systematic review'/exp OR 'meta analysis'/exp | 85,928
#14 | #5 AND #13 | 36
#15 | 'case control study'/exp OR 'cohort analysis'/exp OR 'epidemiological study' OR 'cross-sectional study'/exp OR 'organizational case study' OR 'crossover procedure'/exp OR 'seroepidemiologic study' OR 'epidemiology'/exp OR 'multicenter study'/exp OR 'multicenter study (topic)'/exp OR 'evaluation research'/exp | 1,850,275
#16 | #5 AND #15 | 286
#17 | #5 AND harms | 1
#18 | #8 OR #10 OR #12 OR #14 OR #16 OR #17 | 4571
#19 | #18 NOT #6 | 499

CINAHL: Search Jan. 8, 2012

# | Query | Limiters/Expanders | Last Run Via | Results
S35 | S34 NOT S8 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 126
S34 | S14 or S16 or S18 or S20 or S32 or S33 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 126
S33 | S6 AND harms | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1
S32 | S6 AND S31 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 93
S31 | S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 228629
S30 | (MH "Evaluation Research+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 16072
S29 | (MH "Multicenter Studies") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 5343
S28 | (MH "Seroprevalence Studies") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 295
S27 | (MH "Crossover Design") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 6732
S26 | "organizational case studies" | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 3
S25 | (MH "Cross Sectional Studies") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 45985
S24 | (MH "Epidemiological Research") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 17482
S23 | (MH "Prospective Studies+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 124579
S22 | (MH "Case Control Studies+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 25256
S21 | (MH "Observational Methods+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 11878
S20 | S6 and S19 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 8
S19 | (MH "Meta Analysis") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 11090
S18 | S6 and S17 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 7
S17 | (MH "Systematic Review") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 9517
S16 | S6 and S15 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 33
S15 | "controlled clinical trial" OR (MH "Clinical Trials+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 100728
S14 | S6 and S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 22
S13 | S9 or S10 or S11 or S12 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 46815
S12 | (MH "Random Assignment") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 26792
S11 | (MH "Double-Blind Studies") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 17004
S10 | (MH "Single-Blind Studies") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 4748
S9 | (MH "Randomized Controlled Trials") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 7500
S8 | S6 and S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 9
S7 | (MH "Literature Review+") | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 12381
S6 | S5 | Limiters - Human Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 243
S5 | S3 or S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1475
S4 | TX myringotomy | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 297
S3 | S1 and S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1237
S2 | TX "Histamine Antagonists" OR antihistamine* OR "Steroids" OR oral steroid* OR (nasal* AND topical steroid*) OR "Anti-Bacterial Agents" OR antibiotic* OR complementary medicine* OR alternative medicine* OR complementary therap* OR alternative therap* OR "ear popper" OR manual therap* OR pressure equalization tube* OR adenoidectom* OR "Middle Ear Ventilation" OR tympanostomy OR (middle AND ear*AND tube*) OR (middle AND tympanic* AND tube*) OR grommet* OR ventilation tube* OR tonsillectomy OR "Leukotriene Antagonists/therapeutic use" OR "Leukotriene Antagonists" OR acetate* OR quinolone* OR phosphorylcholine OR combined modality therap* OR "Otologic Surgical Procedures" OR watchful waiting* OR tubulation | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 96206
S1 | TX "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR (sero AND otitis) OR (sero AND muco*) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AND ear*) OR (seromuc* AND middle AND ear*) | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 3096

PubMed supplemental search for CAM: Search Feb 28, 2012

Search | Query | Items found
#1 | Search "Otitis Media with Effusion"[Mesh] | 4555
#2 | Search "Ear, Middle/secretion"[Mesh] | 101
#3 | Search "glue ear"[tiab] | 251
#4 | Search "otitis media"[tiab] | 15224
#5 | Search middle ear effusion* | 1614
#6 | Search (OME[tiab] OR SOM[tiab]) AND (otitis[tiab] OR ear*[tiab]) | 1471
#7 | Search "serous otitis"[tiab] | 612
#8 | Search "secretory otitis"[tiab] | 941
#9 | Search "adhesive otitis"[tiab] | 166
#10 | Search "exudative otitis"[tiab] | 89
#11 | Search (mucoid*[tiab] AND otitis[tiab]) OR (mucous[tiab] AND otitis[tiab]) OR (sero-muco*[tiab] AND otitis[tiab]) OR (sero[tiab] OR muco[tiab] AND otitis[tiab]) OR (otitis[tiab] AND serosa[tiab]) | 414
#12 | Search (mucoid*[tiab] AND middle[tiab] AND ear*[tiab]) OR (mucous[tiab] AND middle[tiab] AND ear*[tiab]) OR (seromuc*[tiab] AND middle[tiab] AND ear*[tiab]) | 463
#13 | Search "nonsuppurative otitis"[tiab] | 0
#14 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 | 17439
#15 | Search "Complementary Therapies"[Mesh] | 155090
#16 | Search "Diet, Sodium-Restricted"[Mesh] | 5155
#17 | Search "Diet, Protein-Restricted"[Mesh] | 1621
#18 | Search "Diet, Carbohydrate-Restricted"[Mesh] | 558
#19 | Search "Diet, Fat-Restricted"[Mesh] | 2350
#20 | Search "Dairy Products"[Mesh] | 66432
#21 | Search dairy OR milk OR cream Or cheese OR butter | 130562
#22 | Search #15 or #16 or #17 or #18 or #19 or #20 or #21 | 294555
#23 | Search #14 and #22 | 230
#24 | Search #23 Limits: Humans | 201
#25 | Search "Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH] | 401536
#26 | Search #24 and #25 | 17

Cochrane Library supplemental search for CAM: Search Feb 28, 2012

ID | Search | Hits
#1 | [underlined: "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR ((sero OR muco) AND otitis) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AND ear*) OR (seromuc* AND middle AND ear*)] | 2292
#2 | [underlined: MeSH descriptor] [underlined: Complementary Therapies] [underlined: explode all trees] | 11569
#3 | [underlined: MeSH descriptor] [underlined: Diet, Sodium-Restricted] [underlined: explode all trees] | 456
#4 | [underlined: MeSH descriptor] [underlined: Diet, Protein-Restricted] [underlined: explode all trees] | 145
#5 | [underlined: MeSH descriptor] [underlined: Diet, Fat-Restricted] [underlined: explode all trees] | 643
#6 | [underlined: MeSH descriptor] [underlined: Diet, Carbohydrate-Restricted] [underlined: explode all trees] | 128
#7 | [underlined: MeSH descriptor] [underlined: Dairy Products] [underlined: explode all trees] | 2342
#8 | [underlined: dairy OR milk OR cream Or cheese OR butter] | 9224
#9 | [underlined: (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8)] | 22097
#10 | [underlined: (#1 AND #9)] | 86
#11 | [underlined: "Randomized Controlled Trial" OR "Single-Blind Method" OR "Double-Blind Method" OR "Random Allocation" OR "Controlled Clinical Trial" OR "Controlled Clinical Trials as Topic" OR (control* AND trial)] | 698608
#12 | [underlined: (#10 AND #11)] | 86

EMBASE supplemental search for CAM: Search Feb 28, 2012

No. | Query | Results
#1 | 'otitis media with effusion'/exp OR 'otitis media with effusion' OR 'otitis media'/exp OR 'otitis media' OR 'middle ear secretion' OR 'ear, middle/secretion' OR 'glue ear'/exp OR 'glue ear' OR middle AND ('ear'/exp OR ear) AND effusion* OR ome OR som OR ('otitis'/exp OR otitis AND ('ear'/exp OR ear)) OR ('otitis'/exp OR otitis AND ears) OR 'nonsuppurative otitis' OR 'serous otitis'/exp OR 'serous otitis' OR 'secretory otitis' OR 'adhesive otitis' OR 'exudative otitis' OR (mucoid AND ('otitis'/exp OR otitis)) OR (mucous AND ('otitis'/exp OR otitis)) OR ('otitis'/exp OR otitis AND ('serosa'/exp OR serosa)) OR (mucoid AND middle AND ('ear'/exp OR ear)) OR (mucous AND middle AND ('ear'/exp OR ear)) AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 23,921
#2 | 'alternative medicine'/exp | 28,963
#3 | 'sodium restriction'/exp | 7,519
#4 | 'protein restriction'/exp | 5,671
#5 | 'low carbohydrate diet'/exp | 1,083
#6 | 'low fat diet'/exp | 5, 811
#7 | 'dairy product'/exp | 74,303
#8 | dairy OR 'milk'/exp OR 'cream'/exp OR 'cheese'/exp OR 'butter'/exp AND ([embase]/lim OR [embase classic]/lim) | 63,357
#9 | #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 | 140,00
#10 | #1 AND #9 | 129
#11 | 'randomized controlled trial'/exp OR 'single blind procedure'/exp OR 'double blind procedure'/exp OR 'random allocation'/exp AND ([embase]/lim OR [embase classic]/lim) | 278.009
#12 | #10 AND #11 | 6

CINAHL supplemental search for CAM: Search Feb 28, 2012

# | Query | Limiters/Expanders | Results
S17 | S11 and S16 | Search modes - Boolean/Phrase
S16 | S12 or S13 or S14 or S15 | Search modes - Boolean/Phrase | 47751
S15 | (MH "Random Assignment") | Search modes - Boolean/Phrase | 27104
S14 | (MH "Double-Blind Studies") | Search modes - Boolean/Phrase | 17138
S13 | (MH "Single-Blind Studies") | Search modes - Boolean/Phrase | 4834
S12 | (MH "Randomized Controlled Trials") | Search modes - Boolean/Phrase | 8205
S11 | S1 and S10 | Search modes - Boolean/Phrase | 465
S10 | S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 | Search modes - Boolean/Phrase | 122594
S9 | TX dairy OR milk OR cream Or cheese OR butter | Search modes - Boolean/Phrase | 33567
S8 | (MH "Dairy Products+") | Search modes - Boolean/Phrase | 2989
S7 | (MH "Dietary Proteins+") | Search modes - Boolean/Phrase | 3917
S6 | (MH "Diet, Low Carbohydrate") | Search modes - Boolean/Phrase | 266
S5 | (MH "Diet, Fat-Restricted") | Search modes - Boolean/Phrase | 1304
S4 | (MH "Restricted Diet+") | Search modes - Boolean/Phrase | 5270
S3 | (MH "Diet, Sodium-Restricted") | Search modes - Boolean/Phrase | 593
S2 | (MH "Alternative Therapies+") | Search modes - Boolean/Phrase | 84028
S1 | TX "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR (sero AND otitis) OR (sero AND muco*) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AN ... | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | 3118

Embase: Update Search August 13, 2012

No. | Query | Results
#1 | 'otitis media with effusion'/exp OR 'otitis media with effusion' OR 'otitis media'/exp OR 'otitis media' OR 'middle ear secretion' OR 'ear, middle/secretion' OR 'glue ear'/exp OR 'glue ear' OR middle AND ('ear'/exp OR ear) AND effusion* OR ome OR som OR ('otitis'/exp OR otitis AND ('ear'/exp OR ear)) OR ('otitis'/exp OR otitis AND ears) OR 'nonsuppurative otitis' OR 'serous otitis'/exp OR 'serous otitis' OR 'secretory otitis' OR 'adhesive otitis' OR 'exudative otitis' OR (mucoid AND ('otitis'/exp OR otitis)) OR (mucous AND ('otitis'/exp OR otitis)) OR ('otitis'/exp OR otitis AND ('serosa'/exp OR serosa)) OR (mucoid AND middle AND ('ear'/exp OR ear)) OR (mucous AND middle AND ('ear'/exp OR ear)) AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 24,807
#2 | 'steroids'/exp OR steroids OR 'oral'/exp OR oral AND steroid* OR (nasal* AND ('topical'/exp OR topical) AND ('steroid'/exp OR steroid)) OR 'antibacterial agents' OR 'anti-bacterial agents' OR antibiotic* OR autoinflation OR 'ear popper' OR manual AND ('therapy'/exp OR therapy) OR 'pressure'/exp OR pressure AND equalization AND ('tube'/exp OR tube) OR 'adenoidectomy'/exp OR adenoidectomy OR 'middle ear ventilation'/exp OR 'middle ear ventilation' OR tympanostomy OR (middle AND ('ear'/exp OR ear) AND ('tube'/exp OR tube)) OR (middle AND tympanic* AND tube*) OR grommet* OR 'ventilation'/exp OR ventilation AND ('tube'/exp OR tube) OR 'tonsillectomy'/exp OR tonsillectomy OR 'leukotriene antagonists/therapeutic use' OR 'leukotriene antagonists'/exp OR 'acetate'/exp OR acetate OR quinolone* OR 'phosphorylcholine'/exp OR phosphorylcholine OR combined AND modality AND ('therapy'/exp OR therapy) OR 'otologic surgical procedures'/exp OR 'otologic surgical procedures' OR watchful AND waiting OR tubulation AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 1916
#3 | #1 AND #2 | 100
#4 | 'myringotomy' OR 'myringotomy'/exp OR myringotomy AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) | 2095
#5 | #3 OR #4 | 2165
#7 | 'alternative medicine'/exp OR 'sodium restriction'/exp OR 'protein restriction'/exp OR 'low carbohydrate diet'/exp OR 'low fat diet'/exp OR 'dairy product'/exp OR dairy OR 'milk'/exp OR 'cream'/exp OR 'cheese'/exp OR 'butter'/exp | 161970
#8 | #1 AND #7 | 140
#9 | #5 OR #8 | 2299
#10 | #9 AND [review]/lim | 330
#11 | #10 AND [humans]/lim AND ([embase]/lim OR [embase classic]/lim) AND [8-12-2011]/sd NOT [13-8-2012]/sd | 23
#12 | 'randomized controlled trial'/exp OR 'single blind procedure'/exp OR 'double blind procedure'/exp OR 'random allocation'/exp | 399,085
#13 | #9 AND #12 | 152
#14 | 'controlled clinical trial'/exp OR 'controlled clinical trial (topic)'/exp | 445,547
#15 | #9 AND #14 | 178
#16 | 'follow up'/exp | 655852
#17 | #9 AND #16 | 209
#18 | 'systematic review'/exp OR 'meta analysis'/exp | 95329
#19 | #9 AND #18 | 44
#20 | 'case control study'/exp OR 'cohort analysis'/exp OR 'epidemiological study' OR 'cross-sectional study'/exp OR 'organizational case study' OR 'crossover procedure'/exp OR 'seroepidemiologic study' OR 'epidemiology'/exp OR 'multicenter study'/exp OR 'multicenter study (topic)'/exp OR 'evaluation research'/exp | 1,979,394
#21 | #9 AND #20 | 324
#22 | #9 AND harms | 1
#23 | #13 OR #15 OR #17 OR #19 OR #21 OR #22 | 641
#24 | #23 AND [humans]/lim AND [8-12-2011]/sd NOT [13-8-2012]/sd | 41
#25 | #11 NOT #24 | 16

CINAHLUpdate: Search Aug 13, 2012

# | Query | Limiters/Expanders | Results
S47 | S26 or S28 or S30 or S32 or S33 or S44 or S45 | Limiters - Published Date from: 20111201–20121231 Search modes - Boolean/Phrase | 7
S46 | S26 or S28 or S30 or S32 or S33 or S44 or S45 | Search modes - Boolean/Phrase | 354
S45 | S17 AND harms | Search modes - Boolean/Phrase | 2
S44 | S17 and S43 | Search modes - Boolean/Phrase | 255
S43 | S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 | Search modes - Boolean/Phrase | 243768
S42 | (MH "Evaluation Research+") | Search modes - Boolean/Phrase | 16705
S41 | (MH "Multicenter Studies") | Search modes - Boolean/Phrase | 5959
S40 | (MH "Seroprevalence Studies") | Search modes - Boolean/Phrase | 307
S39 | (MH "Crossover Design") | Search modes - Boolean/Phrase | 7226
S38 | "organizational case studies" | Search modes - Boolean/Phrase | 3
S37 | (MH "Cross Sectional Studies") | Search modes - Boolean/Phrase | 49996
S36 | (MH "Epidemiological Research") | Search modes - Boolean/Phrase | 18031
S35 | (MH "Prospective Studies+") | Search modes - Boolean/Phrase | 133542
S34 | (MH "Case Control Studies+") | Search modes - Boolean/Phrase | 26734
S33 | S17 AND (MH "Observational Methods+") | Search modes - Boolean/Phrase | 4
S32 | S17 and S31 | Search modes - Boolean/Phrase | 21
S31 | (MH "Meta Analysis") | Search modes - Boolean/Phrase | 11747
S30 | S17 and S29 | Search modes - Boolean/Phrase | 10
S29 | (MH "Systematic Review") | Search modes - Boolean/Phrase | 10937
S28 | S17 and S27 | Search modes - Boolean/Phrase | 132
S27 | "controlled clinical trial" OR (MH "Clinical Trials+") | Search modes - Boolean/Phrase | 106932
S26 | S17 and S25 | Search modes - Boolean/Phrase | 77
S25 | S21 or S22 or S23 or S24 | Search modes - Boolean/Phrase | 50882
S24 | (MH "Random Assignment") | Search modes - Boolean/Phrase | 27917
S23 | (MH "Double-Blind Studies") | Search modes - Boolean/Phrase | 17853
S22 | (MH "Single-Blind Studies") | Search modes - Boolean/Phrase | 5117
S21 | (MH "Randomized Controlled Trials") | Search modes - Boolean/Phrase | 10402
S20 | S17 and S18 | Limiters - Published Date from: 20111201–20121231 Search modes - Boolean/Phrase | 0
S19 | S17 and S18 | Search modes - Boolean/Phrase | 15
S18 | (MH "Literature Review+") | Search modes - Boolean/Phrase | 13858
S17 | S16 | Limiters - Human Search modes - Boolean/Phrase | 618
S16 | S5 or S15 | Search modes - Boolean/Phrase | 1543
S15 | S1 and S14 | Search modes - Boolean/Phrase | 155
S14 | S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 | Search modes - Boolean/Phrase | 108145
S13 | TX dairy OR milk OR cream Or cheese OR butter | Search modes - Boolean/Phrase | 14534
S12 | (MH "Dairy Products+") | Search modes - Boolean/Phrase | 3124
S11 | (MH "Dietary Proteins+") | Search modes - Boolean/Phrase | 4086
S10 | (MH "Diet, Low Carbohydrate") | Search modes - Boolean/Phrase | 289
S9 | (MH "Diet, Fat-Restricted") | Search modes - Boolean/Phrase | 1337
S8 | (MH "Restricted Diet+") | Search modes - Boolean/Phrase | 5458
S7 | (MH "Diet, Sodium-Restricted") | Search modes - Boolean/Phrase | 620
S6 | (MH "Alternative Therapies+") | Search modes - Boolean/Phrase | 87068
S5 | S3 OR S4 | Search modes - Boolean/Phrase | 1472
S4 | TX myringotomy | Search modes - Boolean/Phrase | 306
S3 | S1 AND S2 | Search modes - Boolean/Phrase | 1262
S2 | TX "Histamine Antagonists" OR antihistamine* OR "Steroids" OR oral steroid* OR (nasal* AND topical steroid*) OR "Anti-Bacterial Agents" OR antibiotic* OR complementary medicine* OR alternative medicine* OR complementary therap* OR alternative therap* OR "ear popper" OR manual therap* OR pressure equalization tube* OR adenoidectom* OR "Middle Ear Ventilation" OR tympanostomy OR (middle AND ear*AND tube*) OR (middle AND tympanic* AND tube*) OR grommet* OR ventilation tube* OR tonsillectomy OR "Leukotriene Antagonists/therapeutic use" OR "Leukotriene Antagonists" OR acetate* OR quinolone* OR phosphorylcholine OR combined modality therap* OR "Otologic Surgical Procedures" OR watchful waiting* OR tubulation | Search modes - Boolean/Phrase | 69123
S1 | TX "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR (sero AND otitis) OR (sero AND muco*) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AND ear*) OR (seromuc* AND middle AND ear*) | Search modes - Boolean/Phrase | 3498

Cochrane Library Update: August 13, 2012 Current Search History

ID | Search | Hits
#1 | "Otitis Media with Effusion" OR "otitis media" OR "middle ear secretion" OR "Ear, Middle/secretion" OR "glue ear" OR middle ear effusion* OR OME OR SOM OR (otitis AND ear) OR (otitis AND ears) OR "nonsuppurative otitis" OR "serous otitis" OR "secretory otitis" OR "adhesive otitis" OR "exudative otitis" OR (mucoid AND otitis) OR (mucous AND otitis) OR (sero-muco* AND otitis) OR ((sero OR muco) AND otitis) OR (otitis AND serosa) OR (mucoid AND middle AND ear*) OR (mucous AND middle AND ear*) OR (seromuc* AND middle AND ear*) | 2327
#2 | "Steroids" OR oral steroid* OR (nasal* AND topical steroid*) OR "Anti-Bacterial Agents" OR antibiotic* OR "ear popper" OR manual therap* OR pressure equalization tube* OR adenoidectom* OR "Middle Ear Ventilation" OR tympanostomy OR (middle AND ear*AND tube*) OR (middle AND tympanic* AND tube*) OR grommet* OR ventilation tube* OR tonsillectomy OR "Leukotriene Antagonists/therapeutic use" OR "Leukotriene Antagonists" OR acetate* OR quinolone* OR phosphorylcholine OR combined modality therap* OR "Otologic Surgical Procedures" OR watchful waiting* OR tabulation OR autoinflation | 52955
#3 | MeSH descriptor [underlined: Complementary Therapies] explode all trees | 11802
#4 | MeSH descriptor [underlined: Diet, Sodium-Restricted] explode all trees | 461
#5 | MeSH descriptor [underlined: Diet, Protein-Restricted] explode all trees | 145
#6 | MeSH descriptor [underlined: Diet, Fat-Restricted] explode all trees | 648
#7 | MeSH descriptor [underlined: Diet, Carbohydrate-Restricted] explode all trees | 131
#8 | MeSH descriptor [underlined: Dairy Products] explode all trees | 2375
#9 | dairy OR milk OR cream OR cheese OR butter | 9329
#10 | (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9) | 72917
#11 | (#1 AND #10) | 1142
#12 | (#11 OR myringotomy) | 1243
#13 | Method" OR "Random Allocation" OR "Controlled Clinical Trial" OR "Controlled Clinical Trials as Topic" OR (control* AND trial) | 718613
#14 | (#12 AND #13) | 1225
#15 | ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Epidemiologic Studies"[MeSH] OR "Cross-Sectional Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR "Seroepidemiologic Studies"[MeSH] OR "Multicenter Study"[Publication Type] OR "Multicenter Studies as Topic"[MeSH] OR "Evaluation Studies"[Publication Type] OR "Evaluation Studies as Topic"[MeSH]) | 125753
#16 | (#12 AND #15) | 372
#17 | (#12), from 2011 to 2012 | 139
#18 | (#14 OR #16 OR #17) | 1226
#19 | (#18), from 2011 to 2012 | 139

PubMed Update: August 13, 2012

Search | Query | Items found
#1 | Search "Otitis Media with Effusion"[Mesh] | 4594
#2 | Search "Ear, Middle/secretion"[Mesh] | 101
#3 | Search "glue ear"[tiab] | 252
#4 | Search "otitis media"[tiab] | 15500
#5 | Search middle ear effusion* | 1633
#6 | Search (OME[tiab] OR SOM[tiab]) AND (otitis[tiab] OR ear*[tiab]) | 1507
#7 | Search "nonsuppurative otitis"[tiab] | 0
#8 | Search "serous otitis"[tiab] | 616
#9 | Search "secretory otitis"[tiab] | 945
#10 | Search "adhesive otitis"[tiab] | 168
#11 | Search "exudative otitis"[tiab] | 92
#12 | Search (mucoid*[tiab] AND otitis[tiab]) OR (mucous[tiab] AND otitis[tiab]) OR (sero-muco*[tiab] AND otitis[tiab]) OR (sero[tiab] OR muco[tiab] AND otitis[tiab]) OR (otitis[tiab] AND serosa[tiab]) | 420
#13 | Search (mucoid*[tiab] AND middle[tiab] AND ear*[tiab]) OR (mucous[tiab] AND middle[tiab] AND ear*[tiab]) OR (seromuc*[tiab] AND middle[tiab] AND ear*[tiab]) | 469
#14 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 17740
#15 | Search "Steroids"[Mesh] OR oral steroid* | 665533
#16 | Search nasal*[tiab] AND (topical steroid*[tiab]) | 226
#17 | Search "Anti-Bacterial Agents"[Mesh] OR antibiotic* | 379785
#18 | Search "ear popper"[tiab] OR manual therap*[tiab] | 1042
#19 | Search autoinflation[tiab] | 50
#20 | Search pressure equalization tube*[tiab] | 58
#21 | Search "Adenoidectomy"[Mesh] OR adenoidectom*[tiab] | 3977
#22 | Search "Middle Ear Ventilation"[Mesh] OR tympanostomy[tiab] OR ((middle[tiab] AND (ear*[tiab] OR tympanic[tiab])) AND tube*[tiab]) | 4226
#23 | Search grommet*[tiab] | 448
#24 | Search ventilation tube*[tiab] | 807
#25 | Search "Tonsillectomy"[Mesh] OR tonsillectomy[tiab] | 8769
#26 | Search "Leukotriene Antagonists/therapeutic use"[Mesh] OR "Leukotriene Antagonists" [Pharmacological Action] | 4122
#27 | Search "Acetates/therapeutic use"[Mesh] | 2860
#28 | Search "Quinolines/therapeutic use"[Mesh] | 36041
#29 | Search "Combined Modality Therapy"[Mesh] OR combined modality therap*[tiab] | 183840
#30 | Search myringotomy[tiab] | 1085
#31 | Search "Otologic Surgical Procedures"[Mesh] | 13612
#32 | Search "Phosphorylcholine/administration and dosage"[Mesh] OR "Phosphorylcholine/therapeutic use"[Mesh] | 438
#33 | Search "Watchful Waiting"[Mesh] OR watchful waiting*[tiab] | 1729
#34 | Search tubulation[tiab] | 272
#35 | Search "Complementary Therapies"[Mesh] | 159794
#36 | Search "Diet, Sodium-Restricted"[Mesh] | 5207
#37 | Search "Diet, Protein-Restricted"[Mesh] | 1671
#38 | Search "Diet, Carbohydrate-Restricted"[Mesh] | 600
#39 | Search "Diet, Fat-Restricted"[Mesh] | 2439
#40 | Search "Dairy Products"[Mesh] | 67792
#41 | Search dairy OR milk OR cream Or cheese OR butter | 134103
#42 | Search #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 | 1540392
#43 | Search #14 and #42 | 7300
#44 | Search #43 or #30 | 7858
#45 | Search #43 or #30 Filters: Humans | 6955
#46 | Search "Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH] | 412868
#47 | Search #45 and #46 | 617
#48 | Search #43 or #30 Filters: Humans; Controlled Clinical Trial | 72
#49 | Search #45 AND "Controlled Clinical Trials as Topic"[Mesh] | 142
#50 | Search #47 or #48 or #49 | 786
#51 | Search #45 AND systematic[sb] | 273
#52 | Search #43 or #30 Filters: Humans; Meta-Analysis | 58
#53 | Search #51 or #52 | 273
#54 | Search ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Epidemiologic Studies"[MeSH] OR "Cross-Sectional Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR "Seroepidemiologic Studies"[MeSH] OR "Multicenter Study"[Publication Type] OR “Multicenter Studies as Topic”[MeSH] OR "Evaluation Studies"[Publication Type] OR “Evaluation Studies as Topic”[MeSH]) | 2420779
#55 | Search #45 and #54 | 2719
#56 | Search #45 AND harms | 5
#57 | Search #50 or #53 or #55 or #56 | 3072
#58 | Search #57 AND (2011/06/12:2012/13/08[edat]) | 72
#59 | Search #43 or #30 Filters: Humans; Review | 1028
#60 | Search #59 AND (2011/06/12:2012/13/08[edat]) | 15