# Results

## Introduction

In what follows, we begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each of the two KQs, we begin by listing the key points of the findings, followed by a brief description of included studies, followed by a more detailed synthesis of the evidence. The detailed syntheses under KQ 1 are organized by measures of cough frequency, cough severity, and responsiveness. The detailed syntheses under KQ 2 are organized by comparison drug classes (antitussives, protussives, other agents). We conducted quantitative syntheses where possible, as described in the Methods chapter.

A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, and CDSR yielded 21,860 citations, 6,504 of which were duplicate citations. Manual searching identified 75 additional citations, for a total of 15,431 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 833 full-text articles were retrieved and screened. Of these, 718 were excluded at the full-text screening stage, leaving 115 articles for data abstraction. These 115 articles described 121 unique studies, 78 of which were relevant to KQ 1, and 48 of which were relevant to KQ 2 (5 studies were relevant to both KQs). No additional information was found through our grey literature search.

Figure 2 Literature flow diagram

KQ=Key Question; RCT=randomized controlled trial

^a^ Five studies were relevant to both KQ 1 and KQ 2.

This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed, Embase, and the Cochrane Database of Systematic Reviews yielded 21,860 citations, 6504 of which were duplicate citations. Manual searching identified 75 additional citations, for a total of 15,431 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 833 full-text articles were retrieved and screened. Of these, 718 were excluded at the full-text screening stage, leaving 115 articles (representing 121 unique studies) for data abstraction. Total numbers of studies included for each KQ were 78 for KQ 1, and 48 for KQ 2.

Appendix C provides a detailed listing of included articles. Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

## Description of Included Studies

Overall, we included 121 studies represented by 115 publications: 78 studies were relevant to KQ 1, 48 to KQ 2. Studies were conducted in Europe (54%); the United States or Canada (23%); Australia or New Zealand (11%); Asia (8%); and other locations (8%). Nineteen studies in KQ 1 (23%) and 3 studies in KQ 2 (6%) included children. Forty-five studies (37%) were published before 2000.

Further details are provided in the relevant KQ results sections, below.

## Key Question 1 Instruments Used To Assess Cough

KQ 1: In adults and adolescents (≥ 14 years of age) and children (<14 years of age), what is the comparative diagnostic accuracy, therapeutic efficacy, and patient outcome efficacy of instruments used to assess cough?

### Key Points

- Electronic recording devices are accurate for assessing cough frequency, but they show variable correlation with instruments that measure other dimensions of cough.
- The Leicester Cough Questionnaire (LCQ) and the Cough-specific Quality of Life Questionnaire (CQLQ) are the most widely studied cough-specific quality-of-life questionnaires in adult populations. Both have demonstrated validity and reliability, with emerging evidence available on responsiveness.
- There is moderate strength of evidence to support the validity and responsiveness of the Parent Cough-specific Quality of Life Questionnaire (PC-QOL) in assessing the severity/QOL of cough among children.
- Emerging data support the responsiveness of recording devices, cough-related questionnaires, and tussigenic challenge tests, but further research is needed to accurately estimate the minimally important difference (MID) of these assessment instruments.
- Although diaries and visual analog scales are based on face validity, assess a wide variety of different cough outcomes, and are widely used both in research and practice, there are few data to validate their accuracy in assessing cough, and what data exist show inconsistent correlations with other cough measurement tools. These tools are usually simple and easy to use, but more data are needed to determine their reliability and validity in assessing cough frequency or severity/QOL.
- While all of the included studies evaluated aspects of the comparative diagnostic accuracy of the various cough measurement tools, none evaluated the comparative therapeutic efficacy or patient outcome efficacy of these tools.

### Description of Included Studies

Cough can be assessed along several dimensions, the most of important of which may be frequency, severity, and cough-specific QOL. Cough frequency is objective and relatively easy to measure but may not necessarily correlate with severity or cough-specific QOL, whereas cough severity and cough-specific QOL may be closely interrelated. Most of the standardized questionnaires included in this report measured aspects of both of these latter dimensions. Therefore, for the purpose of this report, we considered instruments that measured both severity and QOL together to be “severity/QOL” instruments. In this CER we evaluate the available data that support the validity and reliability of instruments to measure one of two dimensions of cough: (1) cough frequency; or (2) the severity/QOL impact of cough (including assessments of the impact of cough on sleep, work, general well-being, health-related quality of life, etc.). We also evaluate the available data that support these instruments' ability to measure potentially meaningful clinical change over time (responsiveness).

To be eligible for inclusion in this report, a study had to either: 1) compare a cough frequency or severity/QOL assessment instrument with one or more cough assessment, health-related quality of life, or clinical change instrument; or 2) report data on changes in the instrument score over time in response to treatment for cough or the underlying etiology of the cough. For the purposes of this report, we consider tussigenic challenge tests and exhaled nitric oxide tests as severity/QOL assessments.

In what follows, we rely heavily on tabular presentation of information because of the large degree of heterogeneity with respect to patient populations, study design and objectives, index and reference tests, and the nature and content of the results reported in the individual studies. We summarize the findings of studies of adults and adolescents (≥14 years of age) separately from those of children (<14 years of age). Studies that include adults, adolescents, and children are listed only once in a given table (categorized as “Studies in Adults, Adolescents, and Children”). These studies are included in the study counts in both the “adult and adolescents” and the “children” sections in the text below. Note, however, that their findings are summarized in one or the other of these sections based on the mean age of the included patients and therefore the relevance of the findings to the overall adult or pediatric populations.

A total of 78 studies met the inclusion criteria for this KQ.8,31-106 Seven were RCTs;34,56,59,80,93,96,100 the remaining 71 were observational studies. Nineteen studies (24%) were conducted in the United States or Canada,32,43,45,47,48,50,56,58,60,63,67,74,79,88,90,94,99,102,103 and 39 (50%) in Europe,34,36-39,44,49,51-53,55,59,61,62,64,66,68,70-73,75,77,78,80,81,83,87,89,91,92,95-98,101,105-107 including 32 (41%) conducted exclusively in the UK.36-38,44,49,51-53,55,59,61,62,64,68,70-73,77,78,80,81,83,89,91,92,95-98,101,107 Seven studies took place in Australia/New Zealand,40-42,84-86,104 five in other locations,57,69,76,82,93 and four in multiple locations.46,54,65,100 Geographical location was not reported for four studies.8,31,33,35 In most cases, the funding source was not reported or was unclear. Other study characteristics are summarized in Appendix F (Table F-1). A total of 5,927 participants were included across studies; sample sizes of individual studies ranged from 1 to 671 subjects. Of the 78 studies, 67 (86%) were judged to have a low risk of bias, and 11 (14%) were judged to have a high risk of bias (see Appendix E for details).

Thirty-three studies (42%) enrolled patients with chronic cough of mixed, unknown, or unspecified etiology; 18 (23%) enrolled patients with acute cough or cough of unspecified duration, and 27 (35%) focused on specific clinical conditions such as chronic bronchitis, asthma, or lung cancer. Fifty-nine studies included adults and adolescents (≥14 years of age), 15 included only children (<14 years of age), and 4 included adults, adolescents, and children.

Thirty-two studies (41%) identified a specific cough-related questionnaire as an index test, 22 studies (28%) reported on a specific electronic device designed to measure cough frequency, and 24 (31%) reported on instruments other than cough-related questionnaires or electronic recording devices. Most studies that included other instruments such as visual analog scales, symptom diaries, tussigenic challenges, or self-reported global change items utilized them as validation tools but did not evaluate them as index tests themselves. Few of the included studies provided information regarding previous validation of reference tests. While all of the included studies evaluated aspects of the comparative diagnostic accuracy of these measurement tools, none evaluated their comparative therapeutic efficacy or patient outcome efficacy.

### Detailed Synthesis

#### Measures of Cough Frequency

Our search identified 42 studies that evaluated instruments designed to assess the frequency of cough (Table 5).35-37,41,44,45,47,55,59,62,64,65,71,73-75,77,78,90,95,98,102 Of the 42 studies, 8 (19%) were conducted in the United States or Canada.45-47,74,90,94,102,103 Thirty-seven studies (88%) were judged to have low risk of bias, and 5 (12%) had high risk of bias. A variety of reference standards were employed to validate these instruments, including human count, other electronic recording devices, video recording devices, quality-of-life questionnaires, subjective scoring, and laboratory tussigenic challenges.

Table 5 Results of studies of cough frequency assessment instruments

Study | Index Test | Comparator(s) | Validity Assessed? | Reliability Assessed? | Responsiveness Assessed? | Results
Studies in Adults and Adolescents
Barnabe, 1995^34^ | VAS | NA | No | No | Yes | Mean VAS scores of cough frequency decreased over the 2 days of treatment.
Barry, 2006^35^ | Hull Automatic Cough Counter | Cough count (by a human) | No | Yes | No | SN: 0.80 SP: 0.96 Reproducibility: 100%
Birring, 2008^36^ | Leicester Cough Algorithm | Cough count (by a human) | No | Yes | No | Correlation: 0.9 (p<0.001) (stage 1); 0.93 (p<0.001) (stage 2) SN: 0.91 (stage1); 0.86 (stage 2) SP: 0.99 (stage 1); 0.99 (stage 2) Reliability: (ICC): 0.9
Birring, 2006^37^ | Leicester Cough Monitor | Electronic cough recorder (sound or pressure) | No | Yes | No | Reliability (ICC): 0.8
Birring, 2006^37^ | Leicester Cough Monitor | Leicester Cough Questionnaire | Yes | No | No | Correlation Total score: -0.6 (p=0.03) Physical: -0.6 (p=0.03) Psychological: -0.5 (p=0.08) Social: -0.7 (p=0.01)
Birring, 2006^37^ | Leicester Cough Monitor | Capsaicin tussigenic challenge (C5) | Yes | No | No | Correlation: 0.9 (p=0.008)
Birring, 2006^37^ | Leicester Cough Monitor | Capsaicin tussigenic challenge (C2) | Yes | No | No | Correlation: 0.8 (p≤0.05)
Coyle, 2005^45^ | LifeShirt system | Video cough recorder | No | Yes | No | Overall (95% CI) SN: 78.1 (76.7 to 79.4) SP:99.6 (99.5 to 99.6) PPV: 84.6 (83.3 to 85.8) NPV: 99.4 (99.0 to 99.1) Comparison of nighttime with daytime: SN, SP, PPV, NPV=p<0.0001
Crawford, 2008^46^ | Electronic cough recorder | CASA-Q Cough symptoms | Yes | Yes | Yes | The cough symptom and sputum symptom domains did not correlate with cough recordings.
Decalmer, 2007^49^ | Electronic cough recorder | VAS Cough challenge | Yes | Yes | No | “The repeatability of cough monitoring was excellent,” both for day and night recordings. There was a significant inverse correlation between log10 daytime cough rates and log C5 (Pearson's r=20.45, p=0.001). Subjective cough measures tended to correlate more strongly with objective cough rates for overnight than for daytime recordings and the VAS correlated more strongly than cough scores.
Faruqi, 2011^55^ | Hull Automated Cough Counter | NA | No | No | Yes | Median cough counts were significantly lower 8 weeks after baseline assessment.
Faruqi, 2011^55^ | Hull Automated Cough Counter | Leicester Cough Questionnaire | Yes | No | No | Correlation: -0.62 (p<0.001)
Faruqi, 2011^55^ | Hull Automated Cough Counter | SAS | Yes | No | No | Correlation: 0.54 (p<0.001)
Faruqi, 2011^55^ | Hull Automated Cough Counter | VAS | Yes | No | No | Correlation: 0.38 (p=0.007)
Faruqi, 2011^55^ | Hull Automated Cough Counter | C2 | Yes | No | No | Correlation: -0.45 (p=0.001)
Faruqi, 2011^55^ | Hull Automated Cough Counter | C5 | Yes | No | No | Correlation: -0.55 (p<0.001)
Faruqi, 2011^55^ | Hull Automated Cough Counter | Reproducibility | No | Yes | No | r=0.91, (p<0.001)
Fisman, 2001^57^ | Cough frequency score | Cough severity score | No | No | Yes | Cough severity and cough frequency scores decreased, respectively, from 2.6 ± 1.1 to 0.7 ± 1.0 (p<0.001) and from 6.9 ± 2.2 to 2.1 ± 2.4 (p<0.001).
Freestone, 1997^59^ | Electronic cough recorder | NA | Yes | No | Yes | Correlation: r=0.524 (95% CI, 0.32 to 0.68), p<0.0001 between cough frequency and CSPLs Responsiveness: Decrease in all 3 measures of cough (p<0.001)
Freestone, 1997^59^ | Electronic cough recorder | Score | Yes | No | No | Correlation: NS
Freestone, 1997^59^ | Electronic cough recorder | VAS | Yes | No | No | Correlation: NS
Hsu, 1994^65^ | 24-hour ambulatory recorder and EMG | Cough count | No | Yes | No | Correlation: 0.99, p<0.005
Hsu, 1994^65^ | 24-hour ambulatory recorder and EMG | Score | Yes | No | No | Correlation: 0.96, p<0.005
Kelsall, 2011^72^ | 24-hour cough recording | Cough counts VAS | Yes | Yes | Yes | Intraclass correlation: r=0.98 (p<0.001) Change in cough frequency did not correlate with the change in cough VAS scores or cough scores during the day ( r=0.26; p=0.052, and r=0.23; p=0.08, respectively) and correlated only with cough VAS scores at night ( r=0.45; p=0.001, and r=0.23; p=0.10, respectively).
Kelsall, 2009^70^ | 24-hour ambulatory recorder | Cough challenge | Yes | No | Yes | Log 2 and log 24-hr cough frequency and log overnight cough frequency correlated with cough reflex sensitivity to citric acid (logC5).
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Cough count (by a human) | No | Yes | No | Correlation: Cough epochs vs. cough seconds (r^2^=0.84) Correlation: Cough epochs vs. explosive phases (r^2^=0.80) Correlation: Cough seconds vs. explosive phases (r^2^=0.98)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Daytime VAS | Yes | No | No | Correlation: with explosive phases: r=0.45 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Daytime VAS | Yes | No | No | Correlation: with cough seconds: r=0.44 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Daytime VAS | Yes | No | No | Correlation: with cough epochs: r=0.40 (p=0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Nighttime VAS | Yes | No | No | Correlation: with explosive phases: r=0.67 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Nighttime VAS | Yes | No | No | Correlation: with cough seconds: r=0.64 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Nighttime VAS | Yes | No | No | Correlation: with cough epochs: r=0.60 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Leicester Cough Questionnaire | Yes | No | No | Correlation: with explosive phases: r=-0.53 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Leicester Cough Questionnaire | Yes | No | No | Correlation: with cough seconds: r=-0.53 (p≤0.001)
Kelsall, 2008^71^ | 24-hour ambulatory recorder Parameters measured: cough epochs, explosive phases, cough seconds | Leicester Cough Questionnaire | Yes | No | No | Correlation: with cough epochs: r=-0.46 (p≤0.001)
Key, 2010^73^ | Electronic cough recorder | Cough count (by a human) | No | Yes | No | Correlation: Mean difference 0.9 (±1.7)
Key, 2010^73^ | Electronic cough recorder | VAS | Yes | No | No | Correlation: Day r=0.80 (p<0.001) Night r=0.71 (p=0.001)
Key, 2010^73^ | Electronic cough recorder | Leicester Cough Questionnaire | Yes | No | No | Correlation Total score: -0.80 (p<0.001) Physical: -0.76 (p<0.001) Psychological: -0.76 (p<0.001) Social: 0.74 (p<0.001)
Krahnke, 2004^74^ | Audio cough recorder | NA | No | No | Yes | Cough counts decreased over 3 days of treatment for seasonal allergic rhinitis.
Krahnke, 2004^74^ | Audio cough recorder | Daytime score | Yes | No | No | Correlation: 0.54 (p<0.0001)
Krahnke, 2004^74^ | Audio cough recorder | Nighttime score | Yes | No | No | Correlation: 0.39 (p=0.0006)
Krahnke, 2004^74^ | Audio cough recorder | Daytime plus nighttime score | Yes | No | No | Correlation: 0.51 (p<0.001)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Daytime total cough incidents, score | Yes | No | No | Correlation: 0.63 (p=0.22)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Daytime cough incidents per hour, score | Yes | No | No | Correlation: 0.60 (p=0.29)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Time spent coughing per hour during the day, score | Yes | No | No | Correlation: 0.48 (p=0.1)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Nighttime cough incidents per hour, score | Yes | No | No | Correlation: 0.29 (p=0.34)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Time spent coughing per hour during the night, score | Yes | No | No | Correlation: 0.26 (p=0.4)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Total time spent coughing per hour | Yes | No | No | Correlation: 0.37 (p=0.21)
Krajnik, 2010^75^ | Portable automatic cough analyzer | Total cough incidents per hour | Yes | No | No | Correlation: 0.52 (p=0.066)
Leconte, 2011^105^ | LR102 recording device | Video recorder | No | Yes | No | The cough meter was well tolerated by all but one patient who complained of itching at the electrode sites. The two recording methods produced cough frequencies that were closely correlated (r=0.87 for number of cough episodes per hour; r=0.89 for number of single coughs per hour). There was no systematic difference between the two measures across the spectrum of cough frequency. ICCs were also good (ICC=0.86 for episode [95% CI, 0.75 to 0.92] and 0.88 for single cough [95% CI, 0.78 to 0.93]). The number of coughs per hour measured by the cough meter was significantly higher than that measured by counting coughs on the video recording (number of cough episodes per hour 22.57 vs. 18.77, respectively; number of single coughs per hour 65.22 vs. 52.67, respectively). The mean difference between the two methods was 3.8 for cough episodes per hour (p=0.04) and 12.5 for single coughs per hour (p<0.01).
Marsden, 2008^77^ | Electronic cough recorder | Tussigenic challenge (C5) | Yes | No | No | Correlation: 0.08 (p=0.65)
Marsden, 2008^77^ | Electronic cough recorder | Tussigenic challenge (C2) | Yes | No | No | Correlation: 0.39 (p=-0.03)
Marsden, 2008^77^ | Electronic cough recorder | Score | Yes | No | No | Correlation: 0.32 (p=0.45)
Marsden, 2008^77^ | Electronic cough recorder | Leicester Cough Questionnaire | Yes | No | No | Correlation Total score: 0.54 (p<0.001) Physical: -0.45 (p=0.001) Psychological: -0.48 (p≤0.001) Social: -0.55 (p<0.001)
Matos, 2007^78^ | Leicester Cough Monitor | Cough count (by a human) | No | Yes | No | SN: 97.8 (IQR, 88.1 to 99.1)
Ribeiro, 2007^93^ | Diary VAS | NA | No | No | Yes | There was a significant difference in the cough diaries and VAS scores before and after beclomethasone treatment compared with before and after placebo use (difference of differences, 1.0; 95% CI, 0.4 to 1.5; p=0.002 for diaries; and difference of differences, 1.1; 95% CI, 0.6 to 1.8; p=0.01 for the VAS).
Shaheen, 2011^94^ | Fisman cough frequency score | NA | No | No | Yes | Cough frequency score decreased from 6.2 (SD 1.8) to 3.0 (SD 1.8) in the PPI group and form 6.8 (SD 2.0) to 4.5 (SD 2.5), p=0.3.
Smith, 2006^98^ | Video recorder | Cough count (by a human) | No | Yes | No | Manual counting of cough sounds from digital audio recordings has excellent agreement with simultaneous video recordings in laboratory conditions.
Smith, 2006^97^ | Cough recorder | Cough score VAS | Yes | No | Yes | Correlation with day cough frequency: Change in cough score r=0.34, p=0.204 Change in VAS r=0.47, p=0.070 Correlation with night cough frequency: Change in cough score r=0.19, p=0.510 Change in VAS r=0.81, p=0.001
Smith, 2006^96^ | Cough recorder | Cough challenge Cough score VAS | Yes | No | Yes | There were no significant correlations between the change in time spent coughing and the change in cough threshold (r=20.27; p=0.30), change in cough score (day r=20.07, p=0.78; night r=0.17, p=0.48), or change in VAS (day r=20.07, p=0.79; night r=0.30, p=0.24).
Smith, 2006^95^ | Cough recorder | Tussigenic challenge | Yes | No | No | Subjective measures of cough and cough reflex sensitivity are statistically related to time spent coughing in patients with COPD, but with low-to-moderate levels of correlation.
Smith, 2006^95^ | Cough recorder | Electronic recorder | Yes | No | No | Subjective measures of cough and cough reflex sensitivity are statistically related to time spent coughing in patients with COPD, but with low-to-moderate levels of correlation.
Smith, 2006^95^ | Cough recorder | Score | Yes | No | No | Subjective measures of cough and cough reflex sensitivity are statistically related to time spent coughing in patients with COPD, but with low-to-moderate levels of correlation.
Smith, 2006^95^ | Cough recorder | Cough-specific quality of life | Yes | No | No | Subjective measures of cough and cough reflex sensitivity are statistically related to time spent coughing in patients with COPD, but with low-to-moderate levels of correlation.
Thomas, 1978^102^ | DATA recording system | Cough count (by a human) | No | Yes | No | Reliability (ICC): Coefficient of variation: 1.8% Reproducibility: Able to detect effect of codeine with a probability of <0.01 Accuracy: Group 1 correlation coefficient : 0.99; coefficient of determination=0.98 Group 2 correlation coefficient: -0.94; coefficient of determination=0.88
Woodcock, 2010^100^ | Lifeshirt cough recorder | NA | No | No | Yes | The intervention drug (SCH486757) was associated with reduced cough counts as measured by the Lifeshirt. On day 5, SCH486757 reduced cough counts by a median of 7.0 coughs/hour, codeine reduced counts by 13.8 coughs/hour, and placebo reduced counts by 7.8 coughs/hour over the first 4 hours.
Woolf 1964^103^ | Human cough count Hospital room equipped with a recording system | Human cough count | No | Yes | Yes | There was nearly perfect correlation of cough counts between two human observers. Cough curves were constructed for each of the 4 treatment periods for this single-subject study. For the most part, the cough curves did not cross over the 24-hour study period.
Studies in Adults, Adolescents, and Children
Hamutcu, 2002^62^ | Logan Research (LR 100) cough monitor | Electronic cough recorder | No | Yes | No | Correlation: 0.96, p<0.0001
Paul, 2006^90^ | Accelerometer | Video recorder | No | Yes | No | Correlation: 0.997 (p<0.001)
Studies in Children Only
Archer, 1985^31^ | Cough recorder | Diary | Yes | No | No | There was no correlation between night cough counts and diary card scores for night-time wheeze, daytime wheeze, daytime activity or for 24 hour diary scores calculated for the 24 hour period beginning with, and the period ending with, the night recording.
Chang, 2003^42^ | Ambulatory cough recording | Parent cough score Child cough score Cough challenge | Yes | No | No | Log cough frequency correlated with parent and child recorded log cough score (r(s)=0.42, p=0.02) and r(s)=0.44, p=0.01, respectively). Cough scores did not correlate with cough challenge test.
Chang, 1998^40^ | Electronic cough monitor | Parent-completed diary Child-competed diary | Yes | No | No | The agreement adjusted for chance (Cohen's Kappa) between the subjective and objective presence of daytime cough for the subjects was 100%, and that for controls was 0.61 for child-completed cards and 0.44 for parent-completed cards. When both groups were considered together, the agreement was 0.67 and 0.47, respectively. For night-time cough, the agreement between the subjective and objective presence of cough was poor both in subjects and controls. In the subjects, there was no difference between the parent and child scores.
Chang, 1997^41^ | Holter monitor cough meter | Electronic cough recorder (sound or pressure) | No | Yes | No | Mean difference of -0.3 coughs x h(-1), 95% CI (-0.7, 0.2); limits of agreement -2.2 to 1.7 coughs x h(-1).
Corrigan, 2003^44^ | Logan Research (LR 100) cough monitor | Video cough recorder | No | Yes | No | SN: 81.00% PPV: 0.8
Dales, 1997^47^ | Electronic cough recorder | Cough count (by a human) | No | Yes | No | SN: 80 SP: 95 Accuracy: 90
Dales, 1997^47^ | Electronic cough recorder | Diary | Yes | No | No | Kappa: ≤0.10
Falconer, 1993^53^ | Electronic cough recorder | Diary | Yes | No | No | Mean Kappa between reported and recorded cough was 3.0 (range: -0.17 to 1.0), representing poor agreement beyond chance.
Fuller, 1998^61^ | Video recording | Parent questionnaire Parent diary | Yes | No | No | On the second night of recording the between-subject correlation coefficient for individual coughs and percentage of the night awake was 0.25, p=0.13 (n=37) and for individual coughs and percentage of the night awake and restless was 0.36, p=0.03 (n=37). The within-subject correlation coefficient log % awake time on log number of coughs was 0.26 (p=0.01; r=0.13, SE 0.036) with a residual coefficient of variation of 74%. The within-subject correlation coefficient (log % awake time + % restless) was 0.17 (p=0.02; r=0.016, SE 0.0071) with a residual coefficient of variation of 17%.
Hoskyns, 1991^64^ | Cough recorder | Parental night cough diary | Yes | No | Yes | Correlation: (r=0.588, p<0.02) during medication week; no correlation during placebo week
Newcombe, 2010^86^ | Digital voice recorder | PC-QOL psychological | Yes | No | No | Correlation, Time 1: -0.10 (p=0.521) Correlation, Time 2: -0.28 (p=0.089)
Newcombe, 2010^86^ | Digital voice recorder | PC-QOL physical | Yes | No | No | Correlation, Time 1: -0.21 (p=0.188) Correlation, Time 2: -0.46 (p=0.003)
Newcombe, 2010^86^ | Digital voice recorder | PC-QOL social | Yes | No | No | Correlation, Time 1: -0.11 (p=0.487) Correlation, Time 2: -0.51 (p=0.001)
Newcombe, 2010^86^ | Digital voice recorder | PC-QOL physical | Yes | No | No | Correlation, Time 1: -0.15 (p=0.329) Correlation, Time 2: -0.42 (p=0.008)
Newcombe, 2010^86^ | Cough count/hour | NA | No | No | Yes | Effect size for responsiveness to change over time: 0.19
Zihlif, 2005^101^ | LR100 cough recorder | Parent cough scores | Yes | No | No | There was significant correlation between parental scoring of day and night cough compared with actual number of recorded coughs (r=0.930, p<0.0001 for daytime cough; r=0.711 for nighttime cough, p=0.002).

CASA-Q = Cough and Sputum Assessment Questionnaire; CI = confidence interval; COPD = chronic obstructive pulmonary disease; DATA = Discriminator and Accumulator of Tussive Activity; EMG = electromyogram; ICC = intraclass correlation coefficient; IQR = interquartile range; NA = not applicable; NPV = negative predictive value; NS = not statistically significant; PC-QOL = Parent Cough-specific Quality-of-Life questionnaire; PPV = positive predictive value; SE = standard error; SN = sensitivity; SP = specificity; VAS = visual analog scale

Twenty-four different cough frequency assessment tools were described in the 42 studies summarized above (Appendix F, Table F-2), not including humans counting coughs either during direct observation of patients or from recording devices. Of these 24 cough frequency assessments, all but one (the Fisman Cough Severity Frequency Score) are electronic recording devices.

##### Adults and Adolescents (≥14 Years of Age)

Of the 42 studies that evaluated instruments designed to assess the frequency of cough, 29 (69%) included adults and adolescents, and 2 (5%) included adults, adolescents, and children (Table 5). Most of these studies evaluated the performance of electronic recording devices for the purpose of counting the number of coughs in a given period of time.

Five studies comparing sound recording devices with human cough count or video recording34,36,65,90,98 and one study comparing sound recording devices with another electronic recording device62 showed strong correlation between the measures. Note that the studies by Paul and colleagues90 and Hamutcu and colleagues62 also included children under 14 in their studies, although the mean age of the patients was 28.1 ± 25 and 13.6 ± 2.6 years, respectively. One study comparing sound recording devices with the LCQ showed moderately strong correlation.73 Other studies comparing sound recording devices with other cough measurement tools demonstrated only fair to moderate correlation.37,55,59,70,74,75,77,95,97 In general, the results of studies that evaluated electronic recording devices demonstrated variable sensitivity, good PPV, high correlation coefficients, and excellent specificity and NPV when comparing the recording devices with human cough counts.34-36,45,78

Three studies estimated the sensitivity and specificity of three different cough recording devices to assess cough frequency, with human cough counting as the reference standard.35,36,78 A fourth study102 calculated a correlation coefficient between cough counts as measured by an electronic recording device and human cough count. In all four studies, recording devices and humans reported nearly identical counts. This suggests that recording devices are highly valid as cough-counting instruments, at least in controlled or laboratory settings. Correlation between recording devices and other cough assessment instruments, however, was generally poor to moderate, with reported Spearman coefficient values generally in the 0.30–0.60 range. These findings are consistent with an interpretation of limited validity of recording devices; it is also possible, however, that counting coughs with an electronic recording is a valid way to assess cough frequency, but that cough frequency correlates only moderately with cough severity or QOL, which are the constructs that were usually assessed by the instruments with which recording devices were compared.

Five studies assessed the reliability of recording devices.35-37,55,102 Intraclass correlation coefficients were consistently ≥0.80, with reproducibility reported to be 100 percent in one study.35

##### Children (<14 Years of Age)

Of the 42 studies that evaluated instruments designed to assess the frequency of cough, 11 (26%) included only children under the age of 14, and 2 (5%) included adults, adolescents, and children (Table 5). All 13 of these studies reported on an electronic recording device. Reference tests included another electronic recording device (audio or video) in four studies,41,44,62,90 parent-reported questionnaires, scores, or diaries in five studies,40,42,61,64,101 child-reported scores or diaries in three studies,40,42,47 diaries where it was uncertain whether the parent or child was doing the reporting,31,53 and the PC-QOL instrument in one study.86 There was strong correlation (r ≥ 0.96) between electronic devices, and variable correlation between self-reported or parent-reported instruments and electronic recording devices. Some studies reported no significant relationship between parent or child reporting of cough frequency and the number of coughs identified by recording devices, whereas some reported a significant correlation during daytime but not during nighttime. One study64 reported a significant correlation (r=0.588, p<0.02) between cough frequency assessed by a cough recording device and a parental night cough diary during a week when medication for cough was administered to subjects, but no significant correlation during the placebo week.

Two studies estimated the sensitivity and specificity of two different cough recording devices to assess cough frequency, with human cough counting as the reference standard.44,47 Both demonstrated a sensitivity of approximately 80 percent.

##### Measures of Cough Severity or Quality of Life

We identified 56 studies that reported on instruments designed or purported to assess the severity of cough or the quality of life impact of cough on sleep, work, or an aspect of health-related quality of life (Table 6).8,31-34,37-40,42,43,46,48-52,54-61,63,66-69,71-73,76,77,79-86,88,91-97,99,100,104,106 A variety of reference standards were employed to validate these instruments, including electronic recording devices, quality-of-life questionnaires, subjective scoring, and laboratory tussigenic challenges. Of these studies, 14 (25%) were conducted in the United States or Canada.32,43,46,48,50,56,58,60,63,67,79,88,94,99,107 Forty-seven studies (84%) were judged to have a low risk of bias, and the remaining 9 (16%) to have high risk of bias.

Table 6 Results of studies of cough severity or quality-of-life impact assessments

Study | Index Test | Comparator(s) | Validity Assessed? | Reliability Assessed? | Responsiveness Assessed? | Results
Studies in Adults and Adolescents
Au, 2005^32^ | CBSAS | FEV1 prebronchodilator | Yes | No | No | Spearman coefficient: -0.38 (p<0.01)
Au, 2005^32^ | CBSAS | FEV1 postbronchodilator | Yes | No | No | Spearman coefficient: -0.32 (p<0.01)
Au, 2005^32^ | CBSAS | FVC prebronchodilator | Yes | No | No | Spearman coefficient: -0.44 (p<0.01)
Au, 2005^32^ | CBSAS | FVC postbronchodilator | Yes | No | No | Spearman coefficient: -0.40 (p<0.01)
Au, 2005^32^ | CBSAS | SGRQ Total | Yes | No | No | Spearman coefficient: 0.67 (p<0.01)
Au, 2005^32^ | CBSAS | SGRQ Symptoms | Yes | No | No | Spearman coefficient: 0.67 (p<0.01)
Au, 2005^32^ | CBSAS | SGRQ Activity | Yes | No | No | Spearman coefficient: 0.49 (p<0.01)
Au, 2005^32^ | CBSAS | SGRQ Impact | Yes | No | No | Spearman coefficient: 0.58 (p<0.01)
Au, 2005^32^ | CBSAS | San Diego Shortness of Breath Questionnaire | Yes | No | No | Spearman coefficient: 0.49 (p<0.01)
Baiardini, 2005^33^ | CCIQ | NA | Yes | No | Yes | Spearman coefficient: 0.67 to 0.88 for each item on test-retest Responsiveness: A statistically significant difference was recorded in 16 of the 21 items after treatment
Baiardini, 2005^33^ | CCIQ Sleep/concentration | NA | Yes | No | No | Cronbach's α: 79.98
Baiardini, 2005^33^ | CCIQ Relationship | NA | Yes | No | No | Cronbach's α: 86.98
Baiardini, 2005^33^ | CCIQ Daily life impact | NA | Yes | No | No | Cronbach's α: 69.04
Baiardini, 2005^33^ | CCIQ Mood | NA | Yes | No | No | Cronbach's α: 65.41
Baiardini, 2005^33^ | CCIQ | SF-36 | Yes | No | No | Low correlation, except for “daily life impact” item that correlated with 3 SF-36 domains
Barnabe, 1995^34^ | VAS | NA | Yes | No | Yes | VAS scores of sleep disturbance significantly correlated with the number of nocturnal cough recorded on the second day of treatment.
Berkhof, 2012^106^ | LCQ | NA | No | No | Yes | 11 of 49 patients perceived a significant improvement in cough. In these patients the mean change in the total LCQ score after 12 weeks was 4.3 ± 2.5.
Berkhof, 2012^106^ | LCQ | LCQ Domains; -- Physical; -- Psychological; -- Social; -- Total | No | Yes | No | Reliability: Cronbach's α for internal consistency: 0.67 0.75 0.74 0.86
Berkhof, 2012^106^ | LCQ | LCQ Domains; -- Physical; -- Psychological; -- Social; -- Total | No | Yes | No | Reliability: Intraclass correlation coefficients (95% CI) 0.93 (0.84 to 0.97) 0.79 (0.51 to 0.91) 0.88 (0.72 to 0.95) 0.92 (0.81 to 0.96)
Berkhof, 2012^106^ | LCQ | SRGQ-Total | Yes | No | No | Validity: Spearman correlation coefficients (p-value) LCQ-Total: -0.60 (0.001)
Berkhof, 2012^106^ | LCQ | SF-36; -- Physical functioning; -- Role physical; -- Pain; -- General health; -- Vitality; -- Social functioning; -- Role emotional; -- Mental health | Yes | No | No | LCQ-Total: 0.28 (0.041) LCQ-Total: 0.22 (0.11) LCQ-Total: 0.47 (0.001) LCQ-Total: 0.37 (0.007) LCQ-Total: 0.50 (0.001) LCQ-Total: 0.43 (0.001) LCQ-Total: 0.10 (0.48) LCQ-Total: 0.44 (0.001)
Birring, 2006^37^ | LCQ Total | Cough frequency | Yes | No | No | Spearman coefficient: 0.6 (p<0.05)
Birring, 2006^37^ | LCQ Total | Cough challenge | Yes | No | No | Spearman coefficient: -0.1 (NS)
Birring, 2003^38^ | LCQ Total | Cough severity | Yes | Yes | Yes | Spearman coefficient: -0.72 Cronbach's α: 0.92 Repeatability (intraclass correlation): 0.96 Responsiveness (effect size based on clinical change score): 1.68
Birring, 2003^38^ | LCQ Total | SGRQ | Yes | No | No | Spearman coefficient: -0.54
Birring, 2003^38^ | LCQ Total | SF-36 | Yes | No | No | Spearman coefficient: 0.46
Birring, 2003^38^ | LCQ Physical | NA | No | Yes | Yes | Cronbach's α: 0.79 Repeatability (intraclass correlation): 0.93 Responsiveness (effect size based on clinical change score): 1
Birring, 2003^38^ | LCQ Psychological | NA | No | Yes | Yes | Cronbach's α: 0.89 Repeatability (intraclass correlation): 0.9 Responsiveness (effect size based on clinical change score): 1.75
Birring, 2003^38^ | LCQ Social | NA | No | Yes | Yes | Cronbach's α: 0.85 Repeatability (intraclass correlation): 0.88 Responsiveness (effect size based on clinical change score): 0.84
Braido, 2006^39^ | CCIQ Daily life impact | SF-36 Physical functioning | Yes | No | No | Spearman coefficient: 0.281
Braido, 2006^39^ | CCIQ Daily life impact | SF-36 Vitality | Yes | No | No | Spearman coefficient: 0.291
Braido, 2006^39^ | CCIQ Daily life impact | SF-36 Physical summary | Yes | No | No | Spearman coefficient: 0.333
Chernecky, 2004^43^ | LCCQ | NA | No | Yes | No | Cronbach's α: 0.98 (p<0.001)
Chernecky, 2004^43^ | LCCQ | LCCQ-“How much coughing do you have?” | Yes | No | No | Spearman coefficient: 0.80 (p=0.10)
Crawford, 2008^46^ | CASA-Q Cough symptoms | NA | No | Yes | Yes | Among stable subjects (n=118); p-values NR: Repeatability (intraclass correlation): 0.77 Cronbach's α: 0.85 The mean CASA-Q cough symptom and sputum symptom domain scores indicated responsiveness towards both worse and improved symptoms.
Crawford, 2008^46^ | CASA-Q Cough symptoms | SGRQ Symptoms | Yes | No | No | Spearman coefficient: -0.17 (p=0.0003)
Crawford, 2008^46^ | CASA-Q Cough symptoms | SGRQ Impact | Yes | No | No | Spearman coefficient: -0.32 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Cough symptoms | SGRQ Activities | Yes | No | No | Spearman coefficient: -0.04 (p=0.38)
Crawford, 2008^46^ | CASA-Q Cough symptoms | SGRQ Total | Yes | No | No | Spearman coefficient: -0.25 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Cough impact | NA | No | Yes | No | Among stable subjects (n=118); p-values NR: Repeatability (intraclass correlation): 0.88 Cronbach's α: 0.91
Crawford, 2008^46^ | CASA-Q Cough impact | SGRQ Symptoms | Yes | No | No | Spearman coefficient: -0.23 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Cough impact | SGRQ Impact | Yes | No | No | Spearman coefficient: -0.54 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Cough impact | SGRQ Activities | Yes | No | No | Spearman coefficient: -0.27 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Cough impact | SGRQ Total | Yes | No | No | Spearman coefficient: -0.49 (p<0.0001)
Crawford, 2008^46^ | CASA-Q Sputum symptoms | NA | No | Yes | Yes | Among stable subjects (n=118); p-values NR: Repeatability (intraclass correlation): 0.80 Cronbach's α: 0.80 The mean CASA-Q cough symptom and sputum symptom domain scores indicated responsiveness towards both worse and improved symptoms.
Crawford, 2008^46^ | CASA-Q Sputum impact | NA | No | Yes | No | Among stable subjects (n=118); p-values NR: Repeatability (intraclass correlation): 0.82 Cronbach's α: 0.89
De Vito Dabbs, 2002^48^ | QLTP Total | NA | Yes | Yes | No | Spearman coefficient: 0.7 Cronbach's α: 0.82 Repeatability (intraclass correlation): 0.9
De Vito Dabbs, 2002^48^ | QLTP Respiratory symptoms | NA | No | Yes | No | Cronbach's α: 0.76 Repeatability (intraclass correlation): 0.8
De Vito Dabbs, 2002^48^ | QLTP General symptoms | NA | No | Yes | No | Cronbach's α: 0.8 Repeatability (intraclass correlation): 0.9
De Vito Dabbs, 2002^48^ | QLTP Activities of daily living | NA | No | Yes | No | Cronbach's α: 0.896 Repeatability (intraclass correlation): 0.89
De Vito Dabbs, 2002^48^ | QLTP Total | MSFSD | Yes | No | No | Spearman coefficient: 0.5
De Vito Dabbs, 2002^48^ | QLTP Respiratory symptoms | MSFSD | Yes | No | No | Spearman coefficient: 0.5
De Vito Dabbs, 2002^48^ | QLTP General symptoms | MSFSD | Yes | No | No | Spearman coefficient: 0.51
De Vito Dabbs, 2002^48^ | QLTP Activities of daily living | Functional Performance Inventory | Yes | No | No | Spearman coefficient: 0.7
De Vito Dabbs, 2002^48^ | QLTP Shortness of breath | VAS | Yes | No | No | Spearman coefficient: 0.93
De Vito Dabbs, 2002^48^ | QLTP Severity of cough | VAS | Yes | No | No | Spearman coefficient: 0.87
Decalmer, 2007^49^ | LCQ Total | Log total time spent coughing | Yes | No | No | Spearman coefficient: -0.62 (p≤0.001)
Decalmer, 2007^49^ | LCQ Physical | Log total time spent coughing | Yes | No | No | Spearman coefficient: -0.55 (p≤0.001)
Decalmer, 2007^49^ | LCQ Psychological | Log total time spent coughing | Yes | No | No | Spearman coefficient: -0.59 (p≤0.001)
Decalmer, 2007^49^ | LCQ Social | Log total time spent coughing | Yes | No | No | Spearman coefficient: -0.55 (p≤0.001)
Dicpinigaitis, 2006^50^ | Cough severity score | CES-D | Yes | No | Yes | Improvement in cough score correlated with improvement in depression score (Spearman coefficient=0.323, p=0.003). There was a significant improvement in both cough and depression scores after 3 months (p<0.001).
Doherty, 2000^52^ | Diary VAS | Capsaicin cough test | Yes | No | No | Capsaicin sensitivity was related to symptomatic cough as measured by the diary card score in both asthma and COPD (r=-0.38 and r=-0.44, respectively), but only in asthma and not COPD when measured using a VAS (r=-0.32 and r=-0.44, respectively).
Doherty, 2000^51^ | Diary card VAS | Capsaicin cough test | Yes | No | Yes | Neither diary card scores nor VAS were related to C5 response rate.
Faruqi, 2011^55^ | LCQ Total Cough counts VAS | Repeat LCQ score Cough challenge | Yes | No | Yes | Spearman coefficient: 0.91 (p<0.001) Cough counts correlated well with capsaicin sensitivity and subjective parameters, being strongest for LCQ (r=-0.6, p<0.001). The subjective parameters correlated moderately well amongst themselves (r=0.6, p=0.001) and weakly with capsaicin sensitivity.
Faruqi, 2011^55^ | LCQ Total Cough counts VAS | Hull Cough Counter | Yes | No | No | Spearman coefficient: -0.6 (p<0.001)
Field, 2009^56^ | CQLQ VAS | NA | Yes | No | Yes | The CQLQ scores were grouped by whether the cough disappeared, improved, or did not improve. The scores of patients whose cough did not improve did not change and were poorer than those whose cough resolved (p<0.0001) and those whose cough improved but did not disappear (p<0.0001). A VAS (0 [none] to 10 [very severe]) was used to determine the effects of CRE management on the severity of cough-associated symptoms. At 8 weeks, mean (± SD) chest pain, throat pain, nausea, and stress incontinence scores in women improved 1.7 ± 3.4 (p=0.0004), 0.9 ± 2.7 (p=0.04), 1.0 ± 2.5 (p=0.004), and 0.9 ± 2.3 (p=0.03), respectively.
Fisman, 2001^57^ | Cough severity score | Cough frequency score | No | No | Yes | Overall, the cough frequency score method alone could identify a beneficial modification of cough in 17 (81%) patients and cough severity score method alone in 17 (76%). Using the combined cough frequency/severity scoring, a beneficial modification of cough could be identified in 20 (95%) of patients.
Fletcher, 2010^58^ | CQLQ | GRC | No | No | Yes | Responsiveness: MID=10.58 (SD 10.63)
Fletcher, 2010^58^ | CQLQ | Punum Ladder | No | No | Yes | Responsiveness: MID=21.89 (SD 15.38)
Fletcher, 2010^58^ | GRC 6-month minus baseline score | CQLQ at 6 months | No | Yes | No | Spearman coefficient: 0.673
Fletcher, 2010^58^ | GRC 6-month minus baseline score | CQLQ at 1 month | No | Yes | No | Spearman coefficient: 0.025
Freestone, 1997^59^ | Cough severity score | Cough recorder | No | No | Yes | In both the codeine and placebo groups the median subjective score was 2.0 (IQR, 2.0 to 3.0). This decreased to 1.0 (IQR, 1.0 to 2.0) 90 minutes after treatment (p<0.0001).
French, 2002^60^ | CQLQ Total | NA | No | No | Yes | Posttreatment cure scores were significantly lower (p<0.001) than pretreatment scores in 24 chronic coughers
French, 2002^60^ | CQLQ Total | Repeat testing | No | Yes | No | Cronbach's α: 0.92 Repeatability (intraclass correlation): 0.89 (p<0.001) Test-retest paired t-value: -1.39
French, 2002^60^ | Physical complaints | NA | No | Yes | No | Cronbach's α: 0.85 Repeatability (intraclass correlation): 0.88 (p<0.001) Test-retest paired t-value: -0.92
French, 2002^60^ | Psychosocial issues | NA | No | Yes | No | Cronbach's α: 0.83 Repeatability (intraclass correlation): 0.91 (p<0.001) Test-retest paired t-value: -0.19
French, 2002^60^ | Functional abilities | NA | No | Yes | No | Cronbach's α: 0.86 Repeatability (intraclass correlation): 0.85 (p<0.001) Test-retest paired t-value: -1.21
French, 2002^60^ | Emotional well-being | NA | No | Yes | No | Cronbach's α: 0.70 Repeatability (intraclass correlation): 0.77 (p<0.001) Test-retest paired t-value: -1.44
French, 2002^60^ | Extreme physical complaints | NA | No | Yes | No | Cronbach's α: 0.70 Repeatability (intraclass correlation): 0.93 (p<0.001) Test-retest paired t-value: -0.24
French, 2002^60^ | Personal safety fears | NA | No | Yes | No | Cronbach's α: 0.63 Repeatability (intraclass correlation): 0.75 (p<0.001) Test-retest paired t-value: -1.28
French, 2002^60^ | Personal safety fears | EQ-5D | Yes | No | No | Spearman coefficient: r=-0.30 (p=0.23)
French, 2002^60^ | Personal safety fears | EQ-VAS | Yes | No | No | Spearman coefficient: r=-0.24 (p=0.33)
French, 1998^8^ | ACOS | SIP Total | No | No | Yes | With successful treatment, the average number of ACOS complaints decreased from 8.6 to 1.9 (p<0.001)
French, 1998^8^ | ACOS Exhaustion | SIP Total | Yes | No | No | Spearman coefficient: 0.58 (p<0.001)
French, 1998^8^ | ACOS Lifestyle change | SIP Total | Yes | No | No | Spearman coefficient: 0.54 (p<0.001)
French, 1998^8^ | ACOS Cannot sing in church | SIP Total | Yes | No | No | Spearman coefficient: 0.31 (p=0.05)
French, 1998^8^ | ACOS Hoarseness | SIP Total | Yes | No | No | Spearman coefficient: 0.43 (p=0.006)
French, 1998^8^ | ACOS Aching all over | SIP Total | Yes | No | No | Spearman coefficient: 0.36 (p<0.03)
French, 1998^8^ | Number of ACOS events | SIP-body care and movement | Yes | No | No | Spearman coefficient: 0.31 (p=0.03)
French, 1998^8^ | Number of ACOS events | SIP-home management | Yes | No | No | Spearman coefficient: 0.33 (p=0.02)
French, 1998^8^ | Number of ACOS events | SIP-social interaction | Yes | No | No | Spearman coefficient: 0.46 (p=0.001)
French, 1998^8^ | Number of ACOS events | SIP-alertness behavior | Yes | No | No | Spearman coefficient: 0.45 (p=0.002)
French, 1998^8^ | Number of ACOS events | SIP-communication | Yes | No | No | Spearman coefficient: 0.38 (p=0.009)
French, 1998^8^ | Number of ACOS events | SIP-recreation | Yes | No | No | Spearman coefficient: 0.31 (p=0.04)
Huisman, 2007^66^ | LCQ Total | NA | No | Yes | Yes | Cronbach's α: 0.93 Repeatability (intraclass correlation): 0.93 Responsiveness (average improvement score [95% CI]): 5.28 (4.41 to 6.15)
Huisman, 2007^66^ | LCQ Total | Modified Borg score | Yes | No | No | Spearman coefficient: -0.41
Huisman, 2007^66^ | LCQ Total | HADS | Yes | No | No | Spearman coefficient: -0.42
Huisman, 2007^66^ | LCQ Total | SF-36 General Health | Yes | No | No | Spearman coefficient: 0.41
Huisman, 2007^66^ | LCQ Physical | NA | No | Yes | Yes | Cronbach's α: 0.77 Repeatability (intraclass correlation): 0.86 Responsiveness (average improvement score [95% CI]): 1.42 (1.14 to 1.71)
Huisman, 2007^66^ | LCQ Physical | Modified Borg score | Yes | No | No | Spearman coefficient: -0.37
Huisman, 2007^66^ | LCQ Physical | HADS | Yes | No | No | Spearman coefficient: -0.42
Huisman, 2007^66^ | LCQ Physical | SF-36 General Health | Yes | No | No | Spearman coefficient: 0.54
Huisman, 2007^66^ | LCQ Psychological | NA | No | Yes | Yes | Cronbach's α: 0.84 Repeatability (intraclass correlation): 0.93 Responsiveness (average improvement score [95% CI]):1.77 (1.47 to 2.06)
Huisman, 2007^66^ | LCQ Psychological | Modified Borg score | Yes | No | No | Spearman coefficient: -0.38
Huisman, 2007^66^ | LCQ Psychological | HADS | Yes | No | No | Spearman coefficient: -0.39
Huisman, 2007^66^ | LCQ Psychological | SF-36 General Health | Yes | No | No | Spearman coefficient: 0.28
Huisman, 2007^66^ | LCQ Social | NA | No | Yes | Yes | Cronbach's α: 0.83 Repeatability (intraclass correlation): 0.93 Responsiveness (average improvement score [95% CI]): 2.10 (1.70 to 2.49)
Huisman, 2007^66^ | LCQ Social | Modified Borg score | Yes | No | No | Spearman coefficient: -0.36
Huisman, 2007^66^ | LCQ Social | HADS | Yes | No | No | Spearman coefficient: -0.46
Huisman, 2007^66^ | LCQ Social | SF-36 General Health | Yes | No | No | Spearman coefficient: 0.3
Irwin, 2002^67^ | ACOS VAS | NA | Yes | No | Yes | Before surgery (median, 23.7 days), VAS score was 73.1 ± 6.1, and ACOS score was 15.0 ± 1.1. After surgery (median, 41.2 days and 1 year), cough improved in all, VAS score decreased to 19.1 ± 8.3 and 22.6 ± 8.1 (p=0.001), respectively, and ACOS score decreased to 2.0 ± 1.3 and 3.6 ± 2.3, respectively (p=0.002). VAS scores decreased 75.7% ± 24.3% in the short term after surgery and 64.4% ± 37.7% at 1 year. ACOS scores decreased by 84% ± 29.6% in the short term after surgery and 78.9% ± 37.1% at 1 year. Over time, VAS and ACOS scores correlated significantly with each other (r=0.88, p=0.004).
Jones, 2011^68^ | LCQ Total | Cough symptom score | Yes | No | No | Spearman coefficient: -0.86 (p<0.0001)
Jones, 2011^68^ | LCQ Total | Cough challenge | Yes | No | No | Spearman coefficient: -0.72 (p<0.0001)
Kelsall, 2011^72^ | VAS Cough score | 24-hour cough recording Human cough counts | Yes | No | Yes | Cough scores were not significantly changed with the catheter during the day or at night. Average day and night scores did not show overall reduction. Cough VAS scores fell significantly with the catheter (p=0.002) but there were no differences in VAS scores at night. Averaging day and night cough, VAS scores showed a mean 9.5 mm (SD ± 35) reduction (p<0.001). 72% of subjects reported a decrease on the cough VAS with the catheter in situ. The change in cough frequency did not correlate with the change in cough VAS scores or cough scores during the day (r=0.26, p=0.52 and r=0.23, p=0.08, respectively) and correlated only with cough VAS scores at night (r=0.45, p=0.001 and r=0.23, p=0.10, respectively).
Kelsall, 2008^71^ | LCQ Total | Time spent coughing | Yes | No | No | Spearman coefficient: r=0.36 (p=0.11)
Key, 2010^73^ | LCQ Total | Total cough rates | Yes | No | No | Spearman coefficient: -0.76 (p<0.001)
Key, 2010^73^ | LCQ Physical | NA | Yes | No | No | Spearman coefficient: -0.76 (p<0.001)
Key, 2010^73^ | LCQ Psychological | NA | Yes | No | No | Spearman coefficient: -0.74 (p<0.001)
Key, 2010^73^ | LCQ Social | NA | Yes | No | No | Spearman coefficient: -0.80 (p<0.001)
Key, 2010^73^ | LCQ Total | Day cough rates | Yes | No | No | Spearman coefficient: -0.72 (p<0.001)
Key, 2010^73^ | LCQ Physical | NA | Yes | No | No | Spearman coefficient: -0.72 (p=0.001)
Key, 2010^73^ | LCQ Psychological | NA | Yes | No | No | Spearman coefficient: -0.71 (p=0.001)
Key, 2010^73^ | LCQ Social | NA | Yes | No | No | Spearman coefficient: -0.77 (p<0.001)
Key, 2010^73^ | LCQ Total | Night cough rates | Yes | No | No | Spearman coefficient: -0.46 (p=0.048)
Key, 2010^73^ | LCQ Physical | NA | Yes | No | No | Spearman coefficient: -0.46 (p=0.048)
Key, 2010^73^ | LCQ Psychological | NA | Yes | No | No | Spearman coefficient: -0.55 (p=0.016)
Key, 2010^73^ | LCQ Social | NA | Yes | No | No | Spearman coefficient: -0.46 (p=0.048)
Ma, 2009^76^ | LCQ Total (post-treatment) | NA | No | No | Yes | Responsiveness: 14.2 to 19.5
Ma, 2009^76^ | LCQ Physical (post-treatment) | NA | No | No | Yes | Responsiveness: 6.3 to 13.5
Ma, 2009^76^ | LCQ Psychological (post-treatment) | NA | No | No | Yes | Responsiveness: 6.5 to 17.4
Ma, 2009^76^ | LCQ Social (post-treatment) | NA | No | No | Yes | Responsiveness: 6.7 to 10.7
Ma, 2009^76^ | LCQ Total | SF-36-physical | Yes | No | No | Spearman coefficient: 0.39 (p<0.0001)
Ma, 2009^76^ | LCQ Total | SF-36-mental | Yes | No | No | Spearman coefficient: 0.30 (p<0.001)
Ma, 2009^76^ | LCQ Total | Challenge-log C5 | Yes | No | No | Spearman coefficient: 0.134 (p=0.25)
Marsden, 2008^77^ | LCQ Total | Daytime spent coughing | Yes | No | No | Spearman coefficient: 0.54 (p<0.001)
Monz, 2010^79^ | CASA-Q Cough symptom | PGI-C response-“Very much better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 26.9 (21.30)
Monz, 2010^79^ | CASA-Q Cough symptom | PGI-C response-“Better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 19.4 (22.51)
Monz, 2010^79^ | CASA-Q Cough symptom | PGI-C response-“A little better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 19.8 (20.49)
Monz, 2010^79^ | CASA-Q Cough impact | PGI-C response-“Very much better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 28.6 (21.28)
Monz, 2010^79^ | CASA-Q Cough impact | PGI-C response-“Better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 22.9 (19.41)
Monz, 2010^79^ | CASA-Q Cough impact | PGI-C response-“A little better” | Yes | No | Yes | Mean change in CASA-Q domain score (SD) between day 1 and 43: 19.2 (18.09)
Monz, 2010^79^ | CASA-Q Cough and sputum domain scores | Diary | Yes | No | No | “Pearson correlation coefficients between the cough and sputum diary items and the respective CASA-Q symptom domain scores were moderate to high and ranged from 0.620 to 0.685 at day 8, 0.690 to 0.746 at day 15 and 0.599 to 0.801 at day 43. All correlations were statistically significant (p<0.0001).”
Morice, 2007^80^ | LCQ Symptom diary | Cough challenge | Yes | No | Yes | The mean score for the LCQ was 12.3 (2.5) at baseline, 13.5 (2.7) on placebo (NS) and improving to 15.5 (2.7) on morphine (p<0.01 vs. baseline, p<0.02 vs. placebo). The physical, psychological, and social questions of the LCQ showed a significant improvement in all three subgroups. The daily cough diary showed a rapid and highly significant reduction in the cough score on morphine (3.4 [1.8], p<0.01), whereas placebo had no discernible effect over baseline.
Murray, 2009^81^ | LCQ | SGRQ | Yes | Yes | Yes | Spearman coefficient; -0.7 (p<0.0001) Cronbach's α: 0.96 (95% CI, 0.93 to 0.97) p<0.0001 Repeatability: Median score (IQR) baseline 11.3 (9.3 to13.7) and after 2-wk antibiotics 17.8 (15 to 18.8) p<0.0001. The LCQ had a significant inverse correlation with the SGRQ: Spearman rank correlation coefficient of -0.69 (95% CI, -0.53 to -0.81; p=0.0001).
Mwachari, 2007^82^ | ABSS | NA | No | Yes | Yes | Responsiveness (effect sizes) of the ABSS Baseline, n=649 (mean score 6.3 ± SD 3.6), effect size=0.89 Baseline to 3 days, n=607 (3.0 ± 3.1), effect size=0.89 Baseline to 7 days, n=576 (2.1 ± 2.7) 1.14, effect size=0.89 Baseline to 14 days, n=530 (2.1 ± 2.9) 1.16, effect size=0.89 Item total correlation Dry cough, r=0.453 (p<0.05) Night cough, r=0.462 (p<0.05) The Cronbach's beta coefficient for the ABSS was 0.66, indicating moderate internal consistency based on the standard criterion of ≥0.70 to indicate high internal consistency. As expected, the ABSS for adjacent measurements had higher correlations in comparison with visits farther apart: baseline and 3-day visit (r=0.21), 3-day and 7-day visits (r=0.36), 7-day and 14-day visits (r=0.28) in comparison with baseline and 7-dayvisit (r=0.08), baseline and 14-day visit (r=0.09) and 3-day and 14-day visits (r=0.17).
Nandha, 2000^83^ | Diary | Patient recall Pharmacist assessment | Yes | No | Yes | There was no significant difference in patient recall of relief obtained from the medication and that actually recorded in the diary card for each of the 3 days. Statistically significant correlations were demonstrated between the two assessments obtained between diary cards and poststudy assessment scores of cough symptoms on days 2 and 3 only. The first day symptoms tended to be rated “better” on recall than that recorded in the diary card (p=0.033).
Novitsky, 2002^88^ | ACOS | SIP Patient-graded outcomes of antireflux surgery | Yes | No | Yes | ACOS and SIP scores correlated with improved outcomes. Early improvement in postoperative cough severity and quality of life not only persisted but also improved over long-term followup (p<0.05). Over time, ACOS and SIP scores correlated significantly with each other (r=0.91, p<0.01).
Polley, 2008^91^ | LCQ Total | CQLQ | Yes | No | No | Spearman coefficient: r=-0.56 (p<0.001)
Polley, 2008^91^ | LCQ Total | EQ-5D | Yes | No | No | Spearman coefficient: r=0.60 (p=0.008)
Polley, 2008^91^ | LCQ Total | EQ-VAS | Yes | No | No | Spearman coefficient: r=0.43 (p=0.07)
Raj, 2009^92^ | LCQ Total | GCR Score | No | No | Yes | Responsiveness: MID=1.3 (SD 3.2)
Raj, 2009^92^ | LCQ Physical | NA | No | No | Yes | Responsiveness: MID=0.2 (SD 0.8)
Raj, 2009^92^ | LCQ Psychological | NA | No | No | Yes | Responsiveness: MID=0.2 (SD 1.1)
Raj, 2009^92^ | LCQ Social | NA | No | No | Yes | Responsiveness: MID=0.8 (SD 1.5)
Ribeiro, 2007^93^ | Diary VAS | Respiratory questionnaire | Yes | No | Yes | There was a significant difference in the cough diaries and VAS scores before and after beclomethasone treatment compared with before and after placebo use (difference of differences, 1.0; 95% CI, 0.4 to1.5; p=0.002 for diaries; and difference of differences, 1.1; 95% Cl, 0.6 to 1.8; p=0.01 for the VAS). Neither cough diaries nor VAS scores correlated with questionnaire (r=0.12; p=0.07) or BPT (r=0.23; p=0.06) findings.
Shaheen, 2011^94^ | CQLQ FCSF | NA | No | No | Yes | Subjects in both the PPI and placebo arm experienced significant improvement in CQLQ over baseline scores, subjects in the PPI arm did not show a greater improvement in CQLQ scores compared with placebo (mean improvement 9.8 in the PPI group vs. 5.9 in the placebo group, p=0.3). Mean changes in FCSF scores were not significantly different between PPI and placebo (Severity: 1.0 vs. 0.8, p=0.7; Frequency: 3.2 vs. 2.3, p=0.3).
Singapuri, 2008^107^ | LCQ-Total | Mannitol challenge test C2 | Yes | No | No | Spearman coefficient: r=-0.09 (p=0.77)
Singapuri, 2008^107^ | LCQ-Total | Mannitol challenge test C5 | Yes | No | No | Spearman coefficient: r=0.38 (p=0.2)
Singapuri, 2008^107^ | VAS | Mannitol challenge test C2 | Yes | No | No | Spearman coefficient: r=-0.09 (p=0.77)
Singapuri, 2008^107^ | VAS | Mannitol challenge test C5 | Yes | No | No | Spearman coefficient: r=-0.32 (p=0.29)
Singapuri, 2008^107^ | Mannitol challenge test C2 | NA | No | Yes | No | Repeatability (intraclass correlation): 0.53
Singapuri, 2008^107^ | Mannitol challenge test C5 | NA | No | Yes | No | Repeatability (intraclass correlation): 0.59
Smith, 2006^97^ | Cough score VAS | Cough recording | Yes | No | Yes | Correlation with day cough frequency: Change in cough score r=0.34, p=0.204 Change in VAS r=0.47, p=0.070 Correlation with night cough frequency: Change in cough score r=0.19, p=0.510 Change in VAS r=0.81, p=0.001
Smith, 2006^96^ | Cough score VAS | Cough challenge Ambulatory cough recording | Yes | No | Yes | There were no significant correlations between the change in time spent coughing and the change in cough threshold (r=20.27; p=0.30), change in cough score (day r=20.07, p=0.78; night r=0.17, p=0.48), or change in VAS (day r=20.07, p=0.79; night r=0.30, p=0.24).
Smith, 2006^95^ | CQLQ Total | Time spent coughing | Yes | No | No | Spearman coefficient: r=0.36 (p=0.06)
Vernon, 2010^99^ | CSD | LCQ SF-36 WPAI MOS-SS GRC | Yes | Yes | Yes | CSD total score: Internal consistency (a) on day 1 was 0.89, and on day 8 was 0.96 Reproducibility (intraclass correlation coefficients [ICC]) was 0.68 on day 1 to day 8 and 0.94 on day 8 to day 15 CSD total scores correlated with the VAS (r=0.84, p<0.0001), LCQ total (r=-0.62, p<0.0001) and subscale scores (r=-0.43, p<0.01 to -0.60, p<0.0001), and WPAI subscale scores (r=0.27 [NS] to 0.51, p<0.01). No significant relationships with SF-36 or MOS-SS were found.
Vernon, 2010^99^ | LCQ Total | NA | Yes | No | No | Spearman coefficient: r=-0.62 (p<0.0001)
Vernon, 2010^99^ | LCQ Physical | NA | Yes | No | No | Spearman coefficient: r=-0.43 (p<0.01)
Vernon, 2010^99^ | LCQ Psychological | NA | Yes | No | No | Spearman coefficient: r=-0.56 (p<0.001)
Vernon, 2010^99^ | LCQ Social | NA | Yes | No | No | Spearman coefficient: r=-0.60 (p<0.0001)
Vernon, 2010^99^ | CSD Total | Patient VAS severity rating | Yes | No | No | Spearman coefficient: r=0.84 (p<0.0001)
Vernon, 2010^99^ | CSD Total | Clinician VAS severity rating | Yes | No | No | Spearman coefficient: r=0.35 (p<0.05)
Vernon, 2010^99^ | CSD Total | LCQ Total | Yes | No | No | Spearman coefficient: r=-0.62 (p<0.0001)
Woodcock, 2010^100^ | Cough score VAS | Cough recording | No | No | Yes | There was no significant difference in change in average cough severity scores from baseline to treatment between SCH486757 and placebo (SCH486757 mean baseline=1.98, mean change during treatment=-0.57 (-30.1%); placebo mean baseline=2.01, mean change=-0.49 (-19.7%), p=0.56). Nor were there significant changes in cough severity score for codeine compared with placebo [codeine mean baseline=2.15, mean change=-0.72 (-33.2%), p=0.07compared with placebo).
Studies in Adults, Adolescents, and Children
Hartnick, 2009^63^ | PCQ | NA | No | No | Yes | Authors concluded that “the PCQ is a valid and reliable instrument with which to follow children with chronic cough longitudinally”
Hartnick, 2009^63^ | PCQ | Time point 1 | No | Yes | No | Cronbach's α: 0.914 (p<0.001) Repeatability: Test-retest correlation (stable patients)
Hartnick, 2009^63^ | PCQ | Time point 2 | No | Yes | No | Cronbach's α: 0.951 (p<0.001) Repeatability: Q1=0.5 (p<0.001)
Hartnick, 2009^63^ | PCQ | Time point 3 | No | Yes | No | Cronbach's α: 0.953 (p<0.001) Repeatability: Q2=0.38 (p<0.001) Q3=0.42 (p<0.001) Q4=0.53 (p<0.001) Q5=0.5 (p<0.001)
Kalpaklioglu, 2005^69^ | LCQ Total | NA | No | No | Yes | The effect size of each specific quality-of-life questionnaire was 1 or higher after treatment, whereas it was much lower in the SF-36.
Kalpaklioglu, 2005^69^ | LCQ Total | Audio recording device | Yes | No | No | Spearman coefficient Log explosive phases, 24-hr: -0.53 (p<0.001) Log cough seconds, 24-hr: -0.53 (p<0.001) Log explosive epochs, 24-hr: -0.46 (p<0.001)
Kalpaklioglu, 2005^69^ | LCQ | CQLQ SF-36 | Yes | No | No | Pretreatment symptom scores were significantly correlated with the CQLQ and LCQ scores (beta=.415 and beta=-0.272, respectively, p=0.008) but not with either component of the SF-36.
Kalpaklioglu, 2005^69^ | LCQ CQLQ | SF-36 | Yes | No | No | Authors state: “we showed that specific questionnaires are more effective in assessing the impact of chronic cough on HRQoL” than the SF-36.
Studies in Children Only
Archer, 1985^31^ | Diary | Cough recorder | Yes | No | No | There was no correlation between night cough counts and diary card scores for night-time wheeze, daytime wheeze, daytime activity, or for 24-hour diary scores calculated for the 24-hour period beginning with, and the period ending with, the night recording.
Chang, 2012^104^ | PC-QOL Cough diary | PedsQL | Yes | No | No | Correlation between PC-QOL and duration of cough: -0.01 (p=0.92)
Chang, 2003^42^ | Parent cough score Child cough score | Ambulatory cough recording Cough challenge | Yes | No | No | Log cough frequency correlated with parent and child recorded log cough score (r(s)=0.42, p=0.02) and r(s)=0.44, p=0.01, respectively). Cough scores did not correlate with cough challenge test.
Chang, 1998^40^ | Parent-completed diary Child-competed diary | Electronic cough monitor | Yes | No | No | The agreement adjusted for chance (Cohen's Kappa) between the subjective and objective presence of daytime cough for the subjects was 100%, and that for controls was 0.61 for child-completed cards and 0.44 for parent-completed cards. When both groups were considered together, the agreement was 0.67 and 0.47, respectively. For night-time cough, the agreement between the subjective and objective presence of cough was poor both in subjects and controls. In the subjects, there was no difference between the parent and child scores.
Faniran, 1999^54^ | New (unnamed) questionnaire | NA | Yes | Yes | No | 3-week test-retest revealed a Kappa statistic >0.6 for most of the items. Questions on cough not associated with cold or flu tended to have better test-retest reliability than questions on cough associated with cold or flu.
Fuller, 1998^61^ | Parent questionnaire Parent diary | Video recording Sleep assessment Worries expressed by parents | Yes | No | Yes | On the second night of recording, the between-subject correlation coefficient for individual coughs and percentage of the night awake was 0.25, p=0.13 (n=37), and for individual coughs and percentage of the night awake and restless was 0.36, p=0.03 (n=37). The within-subject correlation coefficient log % awake time on log number of coughs was 0.26 (p=0.01; r=0.13, SE 0.036) with a residual coefficient of variation of 74%. The within-subject correlation coefficient (log % awake time + % restless) was 0.17 (p=0.02; r=0.016, SE 0.0071) with a residual coefficient of variation of 17%. The regression coefficients imply that halving the number of coughs will reduce the percentage awake time on average by 9% (95% CI, 4 to 15%) and percentage awake and restless time by 1% (95% CI, 0 to 2%).
Newcombe, 2011^84^ | PC-QOL Total | NA | No | No | Yes | An anchor-based approach resulted in an MID estimate of 0.9 for overall PC-QOL change and ranged from 0.71 to 0.95 for individual domain PC-QOL change.
Newcombe, 2011^84^ | PC-QOL Total | VCD | Yes | Yes | No | Spearman coefficient: p=-0.70 (p<0.001) Cronbach's α: 0.84
Newcombe, 2011^84^ | PC-QOL Physical | NA | Yes | No | No | Spearman coefficient: p=-0.65 (p<0.001)
Newcombe, 2011^84^ | PC-QOL Psychological | NA | Yes | No | No | Spearman coefficient: p=-0.64 (p<0.001)
Newcombe, 2011^84^ | PC-QOL Social | NA | Yes | No | No | Spearman coefficient: p=-0.55 (p=0.001)
Newcombe, 2010^86^ | PC-QOL Total | VCD | Yes | Yes | Yes | Spearman coefficient: r=-0.55 (p=0.001) Cronbach's α: 0.94 at Time 1; 0.97 at Time 2 Effect size based on clinical change score: 0.39
Newcombe, 2010^86^ | PC-QOL Total | VAS | Yes | No | No | Spearman coefficient: r=-0.55 (p=0.001)
Newcombe, 2010^86^ | PC-QOL Total | Cough counts | Yes | No | No | Spearman coefficient: r=-0.32 (p=0.074)
Newcombe, 2010^86^ | PC-QOL Total | PedsQL (total score) | Yes | No | No | Spearman coefficient: r=0.46 (p<=0.034)
Newcombe, 2010^86^ | PC-QOL Physical | NA | Yes | No | Yes | Effect size based on clinical change score: 0.41
Newcombe, 2010^86^ | PC-QOL Psychological | NA | Yes | No | Yes | Effect size based on clinical change score: 0.32
Newcombe, 2010^86^ | PC-QOL Social | NA | Yes | No | Yes | Effect size based on clinical change score: 0.32
Newcombe, 2008^85^ | PC-QOL | NA | No | No | Yes | All subscales from the psychometric analysis showed significant improvement in parent-reported quality of life following the intervention (all p<0.001).
Newcombe, 2008^85^ | PC-QOL | Cough score | Yes | No | No | Spearman correlation coefficient: r=0.15
Newcombe, 2008^85^ | PC-QOL | PedsQL-psychosocial | Yes | Yes | No | Cronbach's α: r=0.81; Spearman coefficient: r=-0.33
Newcombe, 2008^85^ | PC-QOL | PedsQL-physical | Yes | Yes | No | Cronbach's α: r=0.84; Spearman coefficient: r=-0.47 (p<0.01)
Newcombe, 2008^85^ | PC-QOL | PedsQL-emotional | Yes | Yes | No | Cronbach's α: r=0.71; Spearman coefficient: r=-0.16 (p=NS)
Newcombe, 2008^85^ | PC-QOL | PedsQL-social | Yes | Yes | No | Cronbach's α: r=0.70; Spearman coefficient: r=-0.18 (p<0.01)
Newcombe, 2008^85^ | PC-QOL | PedsQL-school | Yes | Yes | No | Cronbach's α: r=0.70; Spearman coefficient: r=-0.51 (p<0.05)
Newcombe, 2008^85^ | PC-QOL | SF-12-physical | Yes | Yes | No | Cronbach's α: r=0.83; Spearman coefficient: r=-0.14 (p=NS)
Newcombe, 2008^85^ | PC-QOL | SF-12-role physical | Yes | Yes | No | Cronbach's α: r=0.87; Spearman coefficient: r=-0.33 (p=NS)
Newcombe, 2008^85^ | PC-QOL | SF-12-role emotional | Yes | Yes | No | Cronbach's α: r=0.91; Spearman coefficient: r=-0.31 (p<0.05)
Newcombe, 2008^85^ | PC-QOL | SF-12-mental health | Yes | Yes | No | Cronbach's α: r=0.56; Spearman coefficient: r=-0.06 (p=NS)

ABSS = Acute Bronchitis Severity Score; ACOS = Adverse Cough Outcome Survey; AUC = area under the curve; BPT = bronchoprovocation testing; CASA-Q = Cough and Sputum Assessment Questionnaire; CBSAS = Chronic Bronchitis Symptoms Assessment Scale; CCIQ = Chronic Cough Impact Questionnaire; CES-D = Center for Epidemiologic Studies Depression Scale; CI = confidence interval; COPD = chronic obstructive pulmonary disease; CQLQ = Cough-specific Quality of Life Questionnaire; CRE = certified respiratory educator; Cronbach's α = Cronbach's alpha coefficient; CSD = Cough Severity Diary; EQ-5D = EuroQol five dimension component index; EQ-VAS = EuroQol visual analog scale; EuroQol = European Quality of Life questionnaire; FCSF = Fisman Cough Severity/Frequency; FEV1 = forced expiratory volume in 1 second; FVC = forced vital capacity; GRC = Global Rating of Change; HADS = Hospital Anxiety and Depression Scale; IQR = interquartile range; LCCQ = Lung Cancer Cough Questionnaire; LCQ = Leicester Cough Questionnaire; MID = minimally important difference; MOS-SS = Medical Outcomes Study Sleep Scale; MSFSD = Modified Symptom Frequency/Symptom Distress scale; NA = not applicable; NS = not statistically significant; PC-QOL = Parent Cough-Specific Quality-of-Life questionnaire; PedsQL = Pediatric Quality of Life Inventory; PGI-C = Patient Global Impression of Change; PPI = proton pump inhibitor; QLTP = Questionnaire for Lung Transplant Patients; ROC = receiver operating characteristic; SD = standard deviation; SE = standard error; SF-36/SF-12 = Medical Outcomes Study 36-Item/12-Item Short Form Health Survey; SGRQ = St. George's Respiratory Questionnaire; SIP = Sickness Impact Profile; Spearman coefficient = Spearman correlation coefficient; VAS = visual analog scale; VCD = verbal category descriptive scale; WPAI = Work Productivity Index

Of the many cough frequency assessment tools described in the 56 studies summarized above, 14 were cough-related questionnaires (Table 7). Some of these are cough-specific (Leicester Cough Questionnaire [LCQ], Chronic Cough Impact Questionnaire [CCIQ], Cough-specific Quality of Life Questionnaire [CQLQ], Pediatric Cough Questionnaire [PCQ], Parent Cough-specific Quality-of-Life Questionnaire [PC-QOL], Adverse Cough Outcome Survey [ACOS]), while others focus on disease states for which cough is a predominant symptom (Chronic Bronchitis Symptoms Assessment Scale [CBSAS], Cough and Sputum Assessment Questionnaire [CASA-Q], Lung Cancer Cough Questionnaire [LCCQ], Punum Ladder, and Cough Severity Diary [CSD], and the Questionnaire for Lung Transplant Patients [QLTP]). Other instruments are general assessments, such as the Global Rating of Change (GRC) scale. The ACOS has been revised and replaced by the CQLQ. Twelve of the 14 questionnaires were developed and studied in adult populations, and 2 (the PCQ and PC-QOL) were designed for use in pediatric populations.

Table 7 Description of cough severity or quality-of-life impact instruments

Measure | Type of Scale | Population Derived | Domains | No. of Items | Scoring
Adult Populations
Adverse Cough Outcome Survey (ACOS)^a^ | Self-completed HRQOL | Adults with persistent troublesome cough | Psychosocial Physical | 29 | Each item scored as yes or no No information on total score provided
Chronic Bronchitis Symptoms Assessment Scale (CBSAS) | Self-completed Disease-specific | Outpatient adults with stable chronic bronchitis | Symptoms Activity Impact | 15 | Morning -6 items (0-25) Evening -9 items (0-36) Lower scores indicate less severe symptoms
Chronic Cough Impact Questionnaire (CCIQ) | Self-completed HRQOL | Outpatient adults with chronic cough | Sleep/concentration Relationship Daily Life Impact Mood | 21 | Each item individually scored 5 point scale (1=not at all, 2=a little, 3=enough, 4=much, 5=very much)
Cough and Sputum Assessment Questionnaire (CASA-Q) | Self-completed Condition-specific | Adults with chronic bronchitis, COPD with and without sputum | Cough Symptoms Cough Impact Sputum Symptom Sputum Impact | 25 | Each item scored 0-4 (total score 100) Each domain totaled Higher scores associated with fewer symptoms
Cough Severity Diary (CSD) | Self-completed Condition-specific | Adults with chronic or subacute cough | Frequency Intensity Disruptiveness | 7 | 11-point scale ranging from 0 to 10 with anchors on each end (e.g., never to constantly) Higher scores indicate greater severity
Cough-specific Quality of Life Questionnaire (CQLQ) a | Self-completed Condition-specific | Adult smokers | Physical Complaints Psychosocial Issues Functional Abilities Emotional Well-Being Extreme Physical Complaints Personal Safety Fears | 28 | Each item scored on 4-point Likert scale Total score 28-112 Low scores indicate no adverse effect of cough on quality of life
Leicester Cough Questionnaire (LCQ) | Self-completed HRQOL | Outpatient adults with chronic cough | Physical Psychological Social | 19 | 7-point Likert Scale Range 3 to 21 Higher scores indicate better health
Lung Cancer Cough Questionnaire (LCCQ) | Self-completed Condition-specific | Adult women with lung cancer | Not reported | 8 | Scores range from 0-32 Higher scores indicate greater symptom severity
Lung Cancer Wheezing Questionnaire | Self-completed Condition-specific | Adult women with lung cancer | Not reported | 7 | Scores range from 0-18 Higher scores indicate greater symptom severity
Questionnaire for Lung Transplant Patients (QLTP) | Self-completed Condition-specific | Adult single, double or heart/lung transplant | Respiratory symptoms General symptoms Activity of daily living | 48 | Each subscale is summed for a total score of 48 Higher scores indicate greater symptoms
Pediatric Populations
Pediatric Cough Questionnaire (PCQ) | Self-/parent-completed Condition-specific | Children aged 6 to 12 years | Cough questions Cough associated with cold or flu (wet cough) Cough not associated with cold or flu (dry cough) | 12 | Each item scored as yes or no. Information on total score not provided
Parent Cough-specific Quality-of-Life Questionnaire (PC-QOL) | Self-/parent-completed Condition-specific | Children <18 years old with chronic cough | Frequency (emotions, interference, and annoyance) Worry (fragility and serious illness) | 26 | 7-point Likert scale for each item Information on total score not provided

ACOS = Adverse Cough Outcome Survey; CASA-Q = Cough and Sputum Assessment Questionnaire; CBSAS = Chronic Bronchitis Symptoms Assessment Scale; CCIQ = Chronic Cough Impact Questionnaire; CSD = Cough Severity Diary; COPD = chronic obstructive pulmonary disease; CQLQ = Cough-specific Quality of Life Questionnaire; e; HRQOL = health-related quality of life; LCQ = Leicester Cough Questionnaire; LCCQ = Lung Cancer Cough Questionnaire; PCQ = Pediatric Cough Questionnaire; PC-QOL = Parent Cough-Specific Quality-of-Life questionnaire; QLTP = Questionnaire for Lung Transplant Patients

a The ACOS has been revised and replaced by the CQLQ.

##### Adults and Adolescents (≥14 Years of Age)

Forty-five (80%) of the 56 studies that reported on instruments to assess the severity or quality of life impact of cough included adults and adolescents, and 2 (4%) included adults, adolescents, and children (Table 6). Note that the two studies which included adults, adolescents, and children63,69 had populations with a mean age of 38.3 and 6.8 years, respectively; therefore, the latter study by Hartnick and colleagues63 is discussed in more detail in the children only section, below, while the study by Kalpaklioglu69 is included here.

Of the cough-specific questionnaires, the LCQ was the most widely studied, with 19 studies. Four studies demonstrated strong correlation between the LCQ and other cough measurement tools such as electronic recording devices, subjective symptom scores, cough frequency scores, other questionnaires, and tussigenic challenges,38,68,73,81 while most of the remaining studies showed only fair to moderate correlation with a variety of other cough measurement tools, both objective and subjective.8,37,38,49,66,69,76,77,107 The LCQ was developed based on an outpatient adult population with chronic cough, and no studies evaluated its measurement accuracy in the pediatric population. The LCQ has the advantage of ease of administration and interpretation, which is ideal for an ambulatory clinic setting.

Data on the CQLQ were reported in 7 of the 55 studies on cough severity or quality of life impact.56,58,60,69,91,94,95 An additional three studies8,67,68 reported on the ACOS, which represents a prior generation of the CQLQ. The CQLQ, which includes six domains, has been shown to correlate with the LCQ, both of which appear to be better at assessing the impact of chronic cough than the SF-36.^69^ The CQLQ offers an advantage over the LCQ in its ability to capture sex differences in chronic cough because the LCQ, unlike the CQLQ, does not have an item that assesses urinary incontinence as an important side effect of cough.

The other cough-specific questionnaires have been less extensively studied, and although most report good internal correlation, results correlating these instruments with other cough measures or assessing responsiveness have been variable or lacking.

There is no universally accepted reference standard for the assessment of either cough severity or the impact of cough on health-related quality of life. Most studies of disease-specific or general quality-of-life questionnaires evaluate an instrument's validity by correlation of total scores or domain subscores with other cough or respiratory symptom measurement tools. Reliability of questionnaires in adult populations with cough was most commonly assessed by test-retest correlation and measures of internal consistency. Cronbach's alpha was generally high, with values > 0.80 reported for the majority of questionnaires. Repeatability was also generally good, with high intraclass coefficients reported for most of the questionnaires. In the absence of a single reference standard, however, and with application among a wide variety of patient populations, Spearman coefficients in the 0.2–0.8 range do not necessarily suggest that a given instrument is not a valid assessment tool. Nor is the Spearman coefficient an appropriate point of comparison between two different instruments. These findings may best be interpreted as providing evidence that some questionnaires are valid assessments of cough severity or the impact of cough in health-related quality of life, but that there is insufficient evidence to precisely characterize the validity of most of these instruments.

##### Children (p<14 Years of Age)

Nine of the 56 studies (16%) that reported on instruments to assess the severity or quality of life impact of cough included only children under the age of 14, and 2 (4%) included adults, adolescents, and children (Table 6). The vast majority of subjects in the one of these latter two studies were under the age of 14 (mean age was 6.8 years);63 we therefore consider this study to be primarily among children <14 years of age and discuss it below.

Only two named cough-related questionnaires (PC-QOL and PCQ) were evaluated by these 8 studies. In a series of three studies,84-86 Newcomb and colleagues compared the PC-QOL and the PedsQL (a generic quality-of-life instrument), a cough score, the SF-36, VAS, and VCD instruments, and cough counts. Variable correlation was demonstrated with domains of the PedsQL and SF-36. Robust correlation was demonstrated with VAS and VCD scores (r=-0.55 and r=-0.70, p<0.001) but not with cough counts (r=-0.32, p=0.074). Chang et al.104 administered the PC-QOL, the PedsQL (a generic quality-of-life instrument), and a cough diary to 346 children to assess the burden and etiologies associated with chronic cough, and found that the PC-QOL did not correlate with duration of cough (r=-0.01, p=0.92).

A single study evaluated the PCQ. In this study,63 Hartnick et al. performed validation exercises by administering the 5-item PCQ to the parents of 120 children with chronic cough on 3 different occasions. The first two administrations were conducted within 2 weeks of each other, prior to initiating treatment. The third administration was conducted 3 weeks after the second one to determine if the PCQ would accurately reflect parents' perception of how their child's cough had changed following treatment, as assessed by a parent-reported global assessment of change. This study demonstrated test-retest reliability for each of the five PCQ questions, and provided evidence to confirm the PCQ's internal consistency, discriminant validity, and convergent validity.

Three other studies conducted in pediatric populations did not evaluate a named questionnaire. Two compared diaries or cough severity/QOL scores completed by parents and children to an electronic cough monitor,40,42 and one compared a parent questionnaire and parent diary with video recordings and an assessment of children's sleep.61 The results of these three studies suggest that the frequency of children's cough is variably related to parents' self-reported assessments, with a generally stronger relationship between cough frequency and parents' assessment of cough severity or QOL impact during the daytime than at nighttime.

#### Instrument Responsiveness

Of the 78 studies pertinent to KQ 1 identified by our literature search, 36 (46%) provided information on at least one instrument's responsiveness. For this section of the report, we included studies that estimated an instrument's effect size or minimally important difference (MID), or that otherwise commented on the apparent ability of an instrument to assess change over time in cough frequency, cough severity, or response to a tussigenic challenge test. We also included studies that provided comparative data on two or more cough assessments before and after treatment for cough or its underlying etiology. We did not include efficacy, effectiveness, or safety trials of cough treatment strategies that did not directly or indirectly compare two or more cough assessments; such studies comprise essentially the entire published literature of interventions for cough and its underlying etiologies, as well as much of the literature on interventions with cough as a known side effect. Without a comparative analysis of two or more cough assessments as reported by individual study authors, it is difficult or impossible to determine whether a given instrument failed to detect clinical change or whether there was an absence of clinical change resulting from a given intervention.

##### Adults and Adolescents (≥14 Years of Age)

Thirty (83%) of the 36 studies that provided information on at least one instrument's responsiveness included adults and adolescents, and 2 studies (6%) studies included adults, adolescents, and children. Of these, eight studies reported on the LCQ, seven on the CQLQ or ACOS, and two on the CASA-Q. Three studies assessed responsiveness of tussigenic challenge tests. The remaining studies in adult and adolescent populations included information pertaining to responsiveness for a variety of different instruments, including generic health-related quality-of-life instruments, recording devices, unnamed questionnaires, and VAS and diary instruments. Below, we summarize the literature for the studies that reported responsiveness data on the LCQ, CQLQ, ACOS, and CASA-Q.

There is compelling evidence in support of the LCQ's potential ability to detect clinical change over time. Berkhof et al.106 demonstrated that the mean change in total LCQ score after 12 weeks of treatment was 4.3 (SD 2.5) among the 11 (of 49) patients who reported improvement in cough over the course of the 12 weeks. Murray et al.81 reported a change in total LCQ score from 11.3 (95% CI, 9.3 to 13.8) to 17.8 (95% CI, 14.2 to 18.8) associated with a course of antibiotic treatment for exacerbations of bronchiectasis believed to be due to a pulmonary infection. The LCQ demonstrated significant correlation with the St. George Respiratory Questionnaire over the same time period with that same group of bronchiectasis patients. Similar findings were reported by Morice et al.,80 with total LCQ scores increasing from 12.3 (SD 2.5) to 15.5 (SD 2.7) among patients whose cough was treated with morphine. Significant score increases were also noted for all three LCD domains among patients treated with morphine. Patients treated with morphine in this study also demonstrated significant reductions in cough scores as assessed by a daily cough diary, but no significant change over time was noted among patients in the placebo group. Four studies38,66,76,92 in adults and adolescents, and one study in adults, adolescents, and children69 estimated responsiveness indices for the LCQ and its domains; the values of estimates varied across the studies, in part because of different methods and reference tests.

There is also compelling evidence that suggests that the related CQLQ and ACOS instruments are responsive to clinical change. Irwin et al.67 reported strong correlation between VAS and ACOS scores over time and demonstrated that both ACOS and VAS scores changed soon after patients underwent antireflux surgery. French et al.8 demonstrated that with successful treatment of chronic cough, the average number of ACOS complaints decreased from 8.6 to 1.9 (p<0.001), and Novitsky et al.88 demonstrated that both ACOS and Symptom Inventory Profile scores correlated with improved outcomes and with each other. Field et al.56 demonstrated that mean CQLQ scores differed between patients whose cough scores (as assessed by a VAS) had disappeared, improved, or did not improve. Fletcher et al.58 demonstrated the CQLQ's responsiveness relative to a global rating of change instrument and the Punum Ladder, an instrument that allows patients to rate change in both their overall health-related quality of life associated with their cough and on six domains of quality of life associated with the six subscales of the CQLQ. French et al.60 also demonstrated that total and subscale CQLQ scores were significantly lower post-treatment when patients were no longer reporting cough as a complaint. Of the seven studies we identified that reported responsiveness-related information for the CQLQ, only one had ambiguous findings; in a 12-week RCT of proton pump inhibitors versus placebo in patients with chronic cough,94 CQLQ scores demonstrated similar changes in both treatment groups. It is possible, however, that the treatment with proton pump inhibitors was not effective, as opposed to the CQLQ not being a responsive instrument.

Two studies reported on responsiveness of the CASA-Q. Crawford et al. developed this questionnaire and validated it among patients with COPD or chronic bronchitis in Germany, France, and the U.S., using German, French, and English language versions of the questionnaire.46 This study demonstrated the responsiveness of the CASA-Q among patients who reported both worsening or improvement of cough symptoms over an unspecified period of time. Monz et al.79 estimated the mean change in CASA-Q scores over a 6-week period relative to self-reported clinical change as assessed by the Patient Global Impression of Change (PGI-C) instrument. If one considers self-reported clinical change of “a little better” (as assessed by the PGI-C) to indicate a minimally important difference (MID), the estimated MID for the CASA-Q, is 19.8 (SD 21.28). Other MID estimates for the CASA-Q among this patient population can be derived by the data reported in the paper by Monz et al.

##### Children (p<14 Years of Age)

Four studies (11%) reported on responsiveness of standardized cough questionnaires among children aged 14 years or younger, and two studies included adults, adolescents, and children. Three of these studies were conducted by Newcombe and colleagues84-86 on the PC-QOL. These studies included children with chronic cough and their parents. They provide compelling evidence in support of the PC-QOL's responsiveness. All subscales from the psychometric analysis showed significant improvement in parent-reported quality of life following the treatment for cough (all p<0.001), and all improvements in PC-QOL scores derived by clinical impact were significant at p<0.001. Those parents whose children had not ceased coughing reported significantly greater frequency of concern and worries on the CASA-Q than those whose children had ceased coughing. The trend for change scores were found to increase with higher VCD change ratings for the overall CASA-Q scores, as well as for its three subscales. These investigators estimated effect sizes based on clinical change scores as assessed by a VCD.

A fourth study by Fuller and colleagues61 compared parent's perception of their child's cough and sleep disturbance with cough counts through video recording. At the end of the study, 82 percent of parents correctly perceived whether their child's cough was better or worse. Most parents could not, however, comment on whether their child's sleep was disturbed.

A single study reported on responsiveness for the PCQ in children and adolescents (up to 18 years, mean age 6.8 years ± 5.1). Hartnick et al.63 developed this 5-item questionnaire and administered it to the parents of 120 children who presented to a pediatric pulmonology clinic with a chief complaint of cough. The PCQ was administered three times: prior to the first visit; within 2 weeks of the first administration but before any treatment had been instituted so that test-retest reliability could be assessed; and 3 weeks after the second administration to determine if it would accurately reflect the parent's perception of how the child's cough had changed following treatment. The authors found that mean PCQ at posttreatment was significantly different from the mean at pretreatment in cases in which parents reported that their child's cough had either improved (p<0.001) or worsened (p=0.003), whereas mean scores at these two time points were unchanged in cases in which parents reported that their child's cough was unchanged after treatment (p=0.19)

## Key Question 2 Nonspecific Therapies for Chronic Cough

KQ 2: In adults and adolescents (≥14 years of age) and children (<14 years of age), what are the comparative safety and effectiveness of nonspecific (or symptomatic) therapies to treat patients with chronic cough?

a. In patients with unexplained chronic cough
b. In patients with refractory cough with a known underlying etiology

### Key Points

Key points from the Results chapter are:

- A wide variety of pharmaceutical agents have been used to treat the symptom of chronic cough, including opioid, anesthetic, and nonopioid/nonanesthetic antitussives; expectorant and mucolytic protussives; antihistamines; antibiotics; inhaled corticosteroids; and inhaled anticholinergics.
- Patients with unexplained or refractory chronic cough are not well-defined as a population in the evidence base, restricting the applicability of many studies.
- Of the agents reviewed, the opioid and certain nonopioid/nonanesthetic antitussives most frequently demonstrated efficacy for managing the symptom of chronic cough in adults.
- There were several important quality limitations in the literature, including (1) too few good-quality studies focusing on chronic cough; (2) relatively short durations of followup 3) a diversity of outcomes measured across studies, which limited between-study comparisons; and 4) when similar outcomes were assessed across studies, the instruments used were diverse and inconsistent, making comparison and interpretation difficult.
- Data on nonpharmacological therapies for chronic cough were sparse.
- Studies evaluating management of unidentified or refractory chronic cough in children are extremely limited.
- All preparations appeared to be well-tolerated, but side effects and adverse events were uncommonly reported; underreporting side effects and adverse events could limit the assessment of effectiveness of these drugs.

### Description of Included Studies

Sixty-seven (67) comparisons from 48 studies evaluated therapies in patients with chronic cough and met our inclusion criteria. The 48 studies were described in 42 publications.34,80,93,96,103,108-144 Thirty-three of the 48 studies were parallel-group RCTs,34,80,93,108,109,112,115,117-120,122-125,128,130,132-135,137-144 and 12 were randomized crossover studies.96,110,111,113,114,116,121,126,127,129,131,136 The range of years of publication was 1953 to 2012; 32 (76%) of the articles were published before 2000. Only three studies130,138,144 were performed in children. The majority of studies took place in Europe, with 9 in the UK80,96,113,114,118,122,126,129,143 and 17 in other countries in Europe34,108,109,115,116,119,124,125,131,132,139,142 (total of 54%); 8 studies took place in the United States,103,110-112,123,133-135 7 in Asia,117,127,128,136,137,141 5 in Australia/New Zealand,121,130,138,140,^144^1 in Canada,120 and 1 in South America.93 A total of 2923 participants were included across trials; sample sizes were relatively small, ranging from 8 to 214 participants. Duration of followup was relatively short in most studies, ranging from 1 hour to 115 days. Thirty-three studies (69%) had a followup duration of 2 weeks or less. Other study characteristics are summarized in Appendix F (Table F-3). The majority of studies were rated fair in quality (n=29, or 60%); 11 studies were good in quality, and 8 were poor in quality. Fair- and poor-quality studies had the following limitations: limited description of study entry criteria, randomization, and patient population; incomplete followup; less valid statistical analyses (not intention-to-treat, post hoc subgroup analyses); and/or inadequate reporting of methods and findings.

A variety of interventions were studied; these can be broadly categorized into antitussives, protussives, and nonantitussive/nonprotussive interventions. Antitussives were further categorized as opiates, anesthetics, nonpharmacological, or “other” types. Protussives included expectorants, mucolytics, and nonpharmacological therapies. Nonantitussive/nonprotussive pharmacotherapies included antihistamines, antibiotics, anticholinergics and bronchodilators. Figure 3 represents the various classes of interventions and the comparisons among these represented in the included studies. The 48 studies represented 67 different comparisons within or between treatment classes and included studies of 59 individual agents. There were 39 comparisons (58%) with placebo. The most common class comparisons were between other antitussives and placebo (12 comparisons, 18%), followed by comparisons between antitussive opiates and placebo (11 comparisons, 16%) and comparisons between antitussive opiates and other antitussives (10 comparisons, 15%). Fourteen different class comparisons were evaluated by only one or two studies. Only two studies evaluated nonpharmacological interventions.

Figure 3 Overview of intervention class comparisons

This figure shows the number of direct comparisons between treatments evaluated in this report. All of these treatments pertained to KQ2. The most common comparisons were between antitussive (other) and placebo (12 comparisons [18% of the total number of comparisons evaluated]), followed by antitussive (opiates) versus placebo (11 comparisons [16%]), antitussive (other) versus antitussive (opiates) (10 comparison [15%]), antitussive (other) versus antitussive (other) (7 comparisons [10%]), protussive (mucolytic) versus placebo (4 comparisons [6 percent]), and antihistamine versus placebo (3 comparisons, [4 percent]). Two comparisons (3% each) were made between protussive (expectorants) versus placebo, protussive (expectorants) versus antitussive (other), antitussive (opiates) versus antitussive (opiates), antitussive (opiates) versus antitussive (anesthetics), antibiotic versus placebo, and coritcosteroid versus placebo. A single direct comparison (1% each) was made between antitussive (anesthetics) versus placebo, antitussive (anesthetics) versus antitussive (anesthetics), antitussive (nonpharmacological) versus placebo, bronchodilator versus bronchodilator, antihistamine versus antihistamine, protussive (nonpharmacological) versus protussive (nonpharmacological), protussive (mucolytic) versus protussive (mucolytic), and anticholinergic versus placebo.

Within the included studies, a variety of causes for chronic cough were represented, including bronchitis, chronic obstructive pulmonary disease (COPD), asthma, upper airway cough syndrome (UACS), fibrosis, neoplasm, tuberculosis, cystic fibrosis, gastroesophageal reflux disease (GERD), and unexplained cough, among others (Appendix F, Table F-3).

Table 8 details the specific agents used within the different class comparisons. It also lists the categories of outcomes assessed. The most frequent outcomes studied were cough severity/QOL (57 comparisons, 85%) and cough frequency (37 comparisons, 55%). However, even within these outcome categories, the instruments used to measure similar outcomes varied widely across studies. Other outcomes included functional status, tussigenic challenge, global assessment, and adverse effects, among others.

Table 8 Interventions and outcomes assessed

Comparison | No. of Studies | Study | Intervention | Comparator | Cough Severity | Cough Frequency/ Resolution | Nighttime Awakenings | Functional Status | Tussigenic Challenge | Clearance/ Retention | Patient Preference | Global Assessment | Adverse Events^*^ | Drowsiness | Dyspnea
Antibiotic vs. Placebo | 2 | Yousaf, 2010^143^ | Erythromycin | Placebo | X | X | | X | X
Antibiotic vs. Placebo | 2 | Marchant, 2012^144,*^ | Amoxicillin | Placebo | X | X
Anticholinergic vs. Placebo | 1 | Holmes, 1992^121^ | Ipratropium bromide inhaler | Placebo | X | | | | | | | | | | X
Antihistamine vs. Antihistamine | 1 | Lilienfield, 1976^123^ | Diphenhydramine | Diphenhydramine | | X | | | | | | | | X
Antihistamine vs. Placebo | 3 | Reid, 1989^130,*^ | Ketotifen | Placebo | X | | | X
Antihistamine vs. Placebo | 3 | van Asperen, 1992^138,*^ | Ketotifen | Placebo | X
Antihistamine vs. Placebo | 3 | Tanaka, 1996^136^ | Loratadine | Placebo | | | | | X
Antitussive (anesthetics) vs. Antitussive (anesthetics) | 1 | Simon, 1957^134^ | Benzonatate | Linctussal (bencantyl) | X
Antitussive (anesthetics) vs. Antitussive (opiates) | 2 | Simon, 1960^135^ | Benzonatate | Dihydrocodeinone | X | X | | | | | X
Antitussive (anesthetics) vs. Antitussive (opiates) | 2 | Diwan, 1982^117^ | Isoaminile citrate | Clophedianol HCI | | X | | | | | | | X
Antitussive (anesthetics) vs. Placebo | 1 | Simon, 1960^135^ | Benzonatate | Placebo | X | X | | | | | X
Antitussive (nonpharmacological) vs. Placebo | 1 | Vertigan, 2006^140^ | SPEICH-C | Placebo | X | | | | | | | X
Antitussive (opiates) vs. Antitussive (opiates) | 2 | Sevelius, 1971^133^ | Codeine | Codeine | | X
Antitussive (opiates) vs. Antitussive (opiates) | 2 | Sabot, 1977^132^ | Viminol p-OHB | Viminol p-OHB | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Cass, 1953^110^ | Codeine | Dextromethorphan | X | | | | | | | | X | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Cass, 1954^111^ | Codeine | Dextromethorphan | X | | | | | | | | X | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Cass, 1956^112^ | Codeine | Dextromethorphan | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Dierckx, 1981^116^ | Codeine | Glaucine | X | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Matthys, 1983^125^ | Codeine | Dextromethorphan | X | X | | | | | X
Antitussive (opiates) vs. Antitussive (other) | 10 | Gastpar, 1984^119^ | Codeine | Glaucine | X | X
Antitussive (opiates) vs. Antitussive (other) (continued) | 10 | Barnabe, 1995^34^ | Codeine | Moguisteine | X | X
Antitussive (opiates) vs. Antitussive (other) (continued) | 10 | Luporini, 1998^124^ | Dihydrocodeine rhodanate | Levodropropizine | X | | X | | | | | X | | X
Antitussive (opiates) vs. Antitussive (other) (continued) | 10 | Aliprandi, 2004^108^ | Codeine | Levocloperastine | X | X | X
Antitussive (opiates) vs. Antitussive (other) (continued) | 10 | Aliprandi, 2004^108^ | Codeine | Levocloperastine | X | X | X
Antitussive (opiates) vs. Placebo | 11 | Cass, 1953^110^ | Codeine | Placebo | X | | | | | | | | X | X
Antitussive (opiates) vs. Placebo | 11 | Cass, 1954^111^ | Codeine | Placebo | X | | | | | | | | X | X
Antitussive (opiates) vs. Placebo | 11 | Cass, 1956^112^ | Codeine | Placebo | X
Antitussive (opiates) vs. Placebo | 11 | Simon, 1960^135^ | Dihydrocodeinone | Placebo | X | X | | | | | X
Antitussive (opiates) vs. Placebo | 11 | Woolf, 1964^103^ | Codeine | Placebo | | X
Antitussive (opiates) vs. Placebo | 11 | Sevelius, 1971^133^ | Codeine | Placebo | X | X
Antitussive (opiates) vs. Placebo | 11 | Sabot, 1977^132^ | Viminol p-OHB | Placebo | X
Antitussive (opiates) vs. Placebo (continued) | 11 | Dierckx, 1981^116^ | Codeine | Placebo | X | X
Antitussive (opiates) vs. Placebo (continued) | 11 | Matthys, 1983^125^ | Codeine | Placebo | X | X | | | | | X
Antitussive (opiates) vs. Placebo (continued) | 11 | Smith, 2006^96^ | Codeine | Placebo | X | X | | | X | | | | X | X
Antitussive (opiates) vs. Placebo (continued) | 11 | Morice, 2007^80^ | Morphine sulfate | Placebo | X | | | X | X | | | | X
Antitussive (other) vs. Antitussive (other) | 7 | Cass, 1956^112^ | Dextromethorphan | Dextromethorphan | X
Antitussive (other) vs. Antitussive (other) | 7 | Ruhle, 1984^131^ | Glaucine | Dextromethorphan | X | X | | | | | | | X
Antitussive (other) vs. Antitussive (other) | 7 | Del Donno, 1994^115^ | Moguisteine | Dextromethorphan | X | X | | | | | | | X
Antitussive (other) vs. Antitussive (other) | 7 | Aliprandi, 2004^108^ | Levocloperastine | Levodropropizine | X | X | X
Antitussive (other) vs. Antitussive (other) | 7 | Aliprandi, 2004^108^ | Levocloperastine | Levodropropizine | X | X | X
Antitussive (other) vs. Antitussive (other) | 7 | Aliprandi, 2004^108^ | Levocloperastine | Levodropropizine | X | X | X
Antitussive (other) vs. Antitussive (other) | 7 | Aliprandi, 2004^108^ | Levocloperastine | DL-cloperastine | X | X | | | | | | | X
Antitussive (other) vs. Placebo | 12 | Cass, 1953^110^ | Dextromethorphan | Placebo | X | | | | | | | | X
Antitussive (other) vs. Placebo | 12 | Cass, 1954^111^ | Dextromethorphan | Placebo | X | | | | | | | | X
Antitussive (other) vs. Placebo | 12 | Cass, 1956^112^ | Dextromethorphan | Placebo | X
Antitussive (other) vs. Placebo | 12 | Vakil, 1966^137^ | Pipazethate | Placebo | | X
Antitussive (other) vs. Placebo | 12 | Wojcicki, 1975^142^ | Duopect | Placebo | X
Antitussive (other) vs. Placebo | 12 | Dierckx, 1981^116^ | Glaucine | Placebo | X | X
Antitussive (other) vs. Placebo | 12 | Matthys, 1983^125^ | Dextromethorphan | Placebo | X | X | | | | | X
Antitussive (other) vs. Placebo | 12 | Ruhle, 1984^131^ | Glaucine | Placebo | X | X | | | | | | | X
Antitussive (other) vs. Placebo | 12 | Ruhle, 1984^131^ | Dextromethorphan | Placebo | X | X | | | | | | | X
Antitussive (other) vs. Placebo | 12 | Aversa, 1993^109^ | Moguisteine | Placebo | | X
Antitussive (other) vs. Placebo | 12 | Ramsay, 2008^129^ | Dextromethorphan | Placebo | X | | | X | X | | | | X
Antitussive (other) vs. Placebo | 12 | Mukaida, 2011^127^ | Bakumondoto | Placebo | X | X
Antitussive (other) vs. Protussive (expectorants) | 2 | Wojcicki, 1975^142^ | Duopect | Glycerol | X
Antitussive (other) vs. Protussive (expectorants) | 2 | Matts, 1977^126^ | Diphenhydramine | Guaifenesin | | | | | | | X
Bronchodilator vs. Bronchodilator | 1 | Wei, 2010^141^ | Diprophylline | Methoxyphenamine | X | X | | X
Corticosteroid vs. placebo | 2 | Chaudhuri, 2004^113^ | Fluticasone | Placebo | X
Corticosteroid vs. placebo | 2 | Ribeiro, 2007^93^ | Beclomethasone | Placebo | X | X | X
Protussive (expectorants) vs. Placebo | 2 | Wojcicki, 1975^142^ | Glycerol | Placebo | X
Protussive (expectorants) vs. Placebo | 2 | Parvez, 1996^128^ | Guaifenesin | Placebo | X | X
Protussive (mucolytic) vs. Placebo | 4 | Jackson, 1984^122^ | N-acetylcysteine | Placebo | X | | | | | | | X
Protussive (mucolytic) vs. Placebo | 4 | Guyatt, 1987^120^ | Ambroxol | Placebo | X
Protussive (mucolytic) vs. Placebo | 4 | Dueholm, 1992^118^ | N-acetylcysteine | Placebo | X | | | X | | | | | | | X
Protussive (mucolytic) vs. Placebo | 4 | Parvez, 1996^128^ | Bromhexine | Placebo | X | X
Protussive (mucolytic) vs. Protussive (mucolytic) | 1 | Clarke, 1979^114^ | 2-mercapto-ethane-sulphonate | Hypertonic saline | | X | | | | X
Protussive (nonpharmacological) vs. Protussive (nonpharmacological) | 1 | van Hengstum, 1988^139^ | Positive expiratory pressure mask | Forced expiration | | | | | | X

* Three studies included only children.

### Detailed Synthesis

Table 9 summarizes the patient-centered outcomes data collected for each study.

Table 9 Patient-centered outcomes data

Comparison | Study | Cough Severity | Cough Frequency | Nighttime Awakenings | Functional Status | Tussigenic Challenge | Adverse Events | Other Outcomes
Antibiotic vs. Placebo | Yousaf, 2010^143^ | Mean change in cough VAS from baseline to post treatment at 12 wk: Erythromycin=-12 (SD 33) Placebo=2 (SD 29) Difference=10 (-11 to 33) | Geometric mean (log SD) fold change in coughs/24 hr from baseline to post treatment at 12 wk: Erythromycin=0.67 (SD 0.29) Placebo=0.73 (SD 0.66) Difference=1.1 (0.7 to 1.5) | NR | Mean change in LCQ from baseline to post treatment at 12 wk: Erythromycin=1.8 (SD 3.8) Placebo=1.8 (SD 3.8) Difference=0.0 (-2 to 2) | Geometric mean (log SD) fold change in tussigenic citric acid cough challenge test (C2): Erythromycin=1.6 (SD 0.06) Placebo=1.1 (SD 0.4) Difference=0.7 (0.4 to 1.3) | NR | NR
Antibiotic vs. Placebo | Marchant, 2012^144^ | Median verbal category descriptive score at 2 wk: Amoxicillin=0.5 (IQR, 0 to 2) Placebo=2.25 (IQR, 1.15 to 2.9) P=0.02 | % patients with self-reported cough resolution at 2 wk: Amoxicillin=48 Placebo=16 P=0.015 | NR | NR | NR | NR | NR
Anticholinergic vs. Placebo | Holmes, 1992^121^ | Mean daily score for day-time cough over 3 wk of treatment: Ipratropium bromide=1.29 (SD 0.72) Placebo=1.66 (SD 0.74) p<0.05 Mean daily score for nighttime cough over 3 wk of treatment: Ipratropium bromide=0.82 (SD 0.68) Placebo=1.24 (SD 0.87) p<0.05 | NR | NR | NR | NR | NR | Mean daily score for dyspnea associated with coughing bouts over 3 wk of treatment: Ipratropium bromide=0.25 (SD 0.49) Placebo=0.54 (SD 0.67) p<0.05
Antihistamine vs. Antihistamine | Lilienfield, 1976^123^ | NR | 16-hr cough count assessed at day 3: Diphenhydramine 50 mg: 163.8 (SEM 24.2) Diphenhydramine 25 mg: 175.8 (SEM 27.9) | NR | NR | NR | NR | There was little or no apparent correlation between antitussive effectiveness and incidence of drowsiness
Antihistamine vs. Placebo | Reid, 1989^130^ | Mean day symptom score (0-3) rated by parent after 4 mo: Ketotifen=0.34 (SD 0.48) Placebo=0.37 (SD 0.50) Mean night symptom score (0-3) rated by parent after 4 mo: Ketotifen=0.26 (SD 0.43) Placebo=0.30 (SD 0.48) | NR | NR | Reduction in the number of housebound days due to respiratory symptoms: Ketotifen: p=0.036 Placebo: p=NS | NR | NR | NR
Antihistamine vs. Placebo | van Asperen, 1992^138^ | Mean daytime cough severity (0-3) 20 wk after start of trial: Ketotifen=0.99 Placebo=0.76 Mean nighttime cough severity (0-3) 20 wk after start of trial: Ketotifen=0.94 Placebo=0.76 | NR | NR | NR | NR | NR | NR
Antihistamine vs. Placebo | Tanaka, 1996^136^ | NR | NR | NR | NR | No. of coughs induced by ultrasonically nebullised distilled water inhalation: Loratadine=25.3 (baseline), 14.3 (1 hr after treatment) Placebo=26.4 (baseline), 25.1 (1 hr after treatment) p<0.05 | NR | NR
Antitussive (anesthetics) vs. Antitussive (anesthetics) | Simon, 1957^134^ | No. of patients with excellent or good relief at least 2 wk from treatment: Benzonatate=43/52 Linctussal (bencantyl)=22/41 p<0.05 | NR | NR | NR | NR | NR | NR
Antitussive (anesthetics) vs. Antitussive (opiates) | Simon, 1960^135^ | No. of patients with severity lessened: Benzonatate=28/45 Dihydrocodeinone=29/45 | No. of patients with frequency lessened: Benzonatate=32/45 Dihydrocodeinone=30/45 | NR | NR | NR | NR | Patient preference: Benzonatate=27% Dihydrocodeinone=49% p<0.05
Antitussive (anesthetics) vs. Antitussive (opiates) | Diwan, 1982^117^ | NR | Mean 24-hr cough count: Isoaminile citrate=52.5 (SEM 4.01) (baseline), 13.70 (SEM 2.84) (14 days after treatment) Chlophedianol hydrocholaride=63.3 (SEM 3.64) (baseline), 14.2 (SEM 2.66) | NR | NR | NR | Side effects were not troublesome and did not require a reduction in dose or withdrawal of treatment | NR
Antitussive (anesthetics) vs. Placebo | Simon, 1960^135^ | No. of patients with severity lessened: Benzonatate=28/45 Placebo=26/45 | No. of patients with frequency lessened: Benzonatate=32/45 Placebo=30/45 | NR | NR | NR | NR | Patient preference: Benzonatate=27% Placebo=18% p<0.05
Antitussive (nonpharmacological) vs. Placebo | Vertigan, 2006^140^ | Mean score based on cough severity symptoms over last week assessed after 2 mo: Speech therapy=8.8 (SD 2.8) (baseline), 4.9 (SD 3.0) (post intervention) Placebo=7.5 (SD 3.6) (baseline), 6.3 (SD 3.5) (post intervention) p=0.003 | NR | NR | NR | NR | NR | Mean score based on total cough, respiratory, voice, and upper airway symptoms over last week assessed after 2 mo: Speech therapy=35.4 (SD 16.0) (baseline), 22.7 (SD 18.0) (post intervention) Placebo=29.9 (SD 13.5) (baseline), 28.8 (SD 16.5) (post intervention) p<0.001
Antitussive (opiates) vs. Antitussive (opiates) | Sevelius, 1971^133^ | NR | Average reduction in 6-hr posttreatment cough count: Codeine (7.5mg)=29% Codeine (15mg)=42% Codeine (30mg)=56% Codeine (60mg)=67% p<0.005 among doses. | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (opiates) | Sabot, 1977^132^ | Mean cough severity (scale 0-3) assessed over 3 hours, 1 hour after dose: Viminol (70 mg)=3.57 Viminol (140 mg)=2.04 p=0.906 | NR | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Cass, 1953^110^ | Days of cough-suppressing effectiveness over 45 d Dextromethorphan has about 44% of the effectiveness of codeine | NR | NR | NR | NR | No of patients recorded as having side effect sduring 5d study period: Codeine (17 mg)=126 Dextromethorphan (4 mg)=19 | NR
Antitussive (opiates) vs. Antitussive (other) | Cass, 1954^111^ | Intensity of cough (based on Likert scale 0-4) after 35 d: Dextromethorphan=1.28 Codeine=1.26 | NR | NR | NR | NR | Number of patients with side effects after 35 d: Nausea: Dex=3, codeine=13 Vomiting: Dex=0, codeine=3 Constipation: Dex=1, codeine=3 Drowsiness: Dex=1, codeine=18 Sleepiness: Dex=1, codeine=1 | NR
Antitussive (opiates) vs. Antitussive (other) | Cass, 1956^112^ | Mean daily cough score (0-4) over the 10 days: Codeine=0.78 Dextromethorphan=0.86 | NR | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Dierckx, 1981^116^ | Patient judgment on efficacy of treatment 8 hr after single dose (1-5): Codeine=2.45 Glaucine=2.76 | Nocturnal cough counts 8 hr after single treatment Codeine=201.9 (SEM 29.9) Glaucine=241.8 (SEM 29.9) 0.1<P<0.2 | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Matthys, 1983^125^ | Cough intensity on scale of 0-10: Codeine=4.6 (SD 1.5) (baseline), 4.5 (SD 1.6) (after 8 hr) Dextromethorphan=4.4 (SD 1.5) (baseline), 2.9 (SD 1.9) (after 8 hr) p<0.0008 | Nocturnal night counts per hr: Codeine=9.8 (SD 7.5) (baseline), 4.9 (SD 4.3) (after 8 hr) Dextromethorphan=9.5 (SD 6.9) (baseline), 3.4 (SD 3.4) (after 8 hr) | NR | NR | NR | NR | Patient preference (% patients rating) Codeine=12.5% (Best), 12.5% (Worst) Dextromethorphan=87.5% (Best), 6.25% (Worst) p<0.001
Antitussive (opiates) vs. Antitussive (other) | Gastpar, 1984^119^ | Physician score between 0-3: Codeine=3.0 (baseline), 2.00 (SEM 0.03) (3 days), 1.10 (SEM 0.07) (7 days) Glaucine=3.0 (baseline), 1.60 (SEM 0.07) (3 days), 0.47 (SEM 0.07) (7 days) p<0.001 VAS score between 0-100: Codeine=83.3 (SEM 0.7) (baseline), 50.1 (SEM 1.2) (3 days), 16.9 (SEM 1.6) (7 days) Glaucine=85.2 (SEM 0.5) (baseline), 38.6 (SEM 1.6) (3 days), 7.1 (SEM 0.7) (7 days) p<0.001 | No. of patients with cough absent at day 7: Codeine=0 Glaucine=24 p<0.01 | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Barnabe, 1995^34^ | VAS score between 0-100: Codeine=57.9 (baseline), 35.6 (2 days after treatment) Moguisteine=54.8 (baseline), 37.6 (2 days after treatment) | Morning coughs during 6 hr: Codeine=203 (SD 281) (baseline), 137 (SD 196) (3 days after first dose) Moguisteine=243 (SD 248) (baseline), 192 (SD 237) (3 days after first dose) Nocturnal coughs per hr: Codeine=16 (SD 14) (baseline), 8 (SD 10) (3 days after first dose) Moguisteine=27 (SD 32) (baseline), 16 (SD 18) (3 days after first dose) VAS score between 0-100: Codeine=54.8 (baseline), 39.0 (2 days after treatment) Moguisteine=61.8 (baseline), 34.6 (2 days after treatment) | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Luporini, 1998^124^ | Patient-reported score between 1-5: Dihydrocodeine=3.7 (SEM 0.6) (baseline), 2.47 (SEM 0.12) (7 days) Levodropropizine=3.7 (SEM 0.6) (baseline), 2.50 (SEM 0.12) (7 days) | NR | Nighttime awakenings: Dihydrocodeine=1.1 (SD 1.5) (baseline), 0.6 (SD 1.1) (7 days) Levodropropizine=1.4 (SD 1.9) (baseline), 1.2 (SD 1.7) (7 days) | NR | NR | NR | Drowsiness: Dihydrocodeine=15/69 (22%) Levodropropizine=5/66 (8%) p<0.05 No severe somnolence was recorded after treatment with either drug Global Assessment (Clearance): Dihydrocodeine=12% (patient assessment) =7% (physician assessment) Levodropropizine=11% (patient assessment) =7% (physician assessment) Global Assessment (Improvement): Dihydrocodeine=76% (patient assessment) =83% (physician assessment) Levodropropizine=67% (patient assessment) =73% (physician assessment)
Antitussive (opiates) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Codeine=2.57 (baseline), 0.30 (end of treatment mean 15.6 days) Levocloperastine=2.00 (baseline), 0.13 (end of treatment mean 15.6 days) | Mean score between 0-4: Codeine=2.77 (baseline), 0.37 (end of treatment mean 15.6 days) Levocloperastine=2.55 (baseline), 0.12 (end of treatment mean 15.6 days) | Mean score between 0-4: Codeine=2.07 (baseline), 0.12 (end of treatment mean 15.6 days) Levocloperastine=2.03 (baseline), 0.02 (end of treatment mean 15.6 days) | NR | NR | NR | NR
Antitussive (opiates) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Codeine=2.53 (baseline), 0.23 (end of treatment mean 10.2 days) Levocloperastine=2.37 (baseline), 0.13 (end of treatment mean 9.8 days) | Mean score between 0-4: Codeine=2.63 (baseline), 0.23 (end of treatment mean 10.2 days) Levocloperastine=2.50 (baseline), 0.10 (end of treatment mean 9.8 days) | Mean score between 0-4: Codeine=1.97 (baseline), 0.13 (end of treatment mean 10.2 days) Levocloperastine=1.60 (baseline), 0.07 (end of treatment mean 9.8 days) | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Cass, 1953^110^ | Mean intensity of cough after 5 days of treatment: Codeine (17 mg)=1,1 Placebo=1.52 | NR | NR | NR | NR | No. of patients recorded as having side effects during 5d study period: Codeine (17 mg)=126 Placebo=17 | NR
Antitussive (opiates) vs. Placebo | Cass, 1954^111^ | Intensity of cough (based on Likert scale 0-4) after 35 d: Codeine=1.26 Placebo=1.49 | NR | NR | NR | NR | Number of patients with side effects after 35 d: Nausea: codeine=13, placebo=3 Vomiting: codeine=3, placebo=0 Constipation: codeine=3, placebo=0 Drowsiness: codeine=18, placebo=2 Sleepiness: codeine=1, placebo=0 | NR
Antitussive (opiates) vs. Placebo | Cass, 1956^112^ | Mean daily cough score (0-4) over the 10 days: Codeine=0.78 Placebo=1.15 | NR | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Simon, 1960^135^ | No. of patients with severity lessened: Dihydrocodeinone=29/45 Placebo=26/45 | No. of patients with frequency lessened: Dihydrocodeinone=30/45 Placebo=30/45 | NR | NR | NR | NR | Patient preference: Dihydrocodeinone=49% Placebo=18% p<0.05
Antitussive (opiates) vs. Placebo | Woolf, 1964^103^ | NR | Average number of daily cough counts over 4d Codeine=359 Placebo=513 Average number of 2-hour post-treatment coughs Codeine=27 Placebo=51 | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Sevelius, 1971^133^ | NR | Average reduction compared with placebo in diurnal cough counts: Codeine (7.5mg)=29% Codeine (15mg)=42% Codeine (30mg)=56% Codeine (60mg)=67% p<0.005 | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Sabot, 1977^132^ | Mean score (0-3) assessed over 3-hr period 1 hr after dose: Placebo=3.66 Viminol p-OHB (140 mg)=2.04; p<0.05 Viminol p-OHB (70 mg)=3.57; p=0.91 | NR | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Dierckx, 1981^116^ | Patient judgment on efficacy of treatment 8 hr after single dose (1-5): Codeine=2.45 Placebo=2.66 | Nocturnal cough counts 8 hr after single treatment Codeine=201.9 (SEM 29.9) Placebo=269.3 (SEM 31.3) P<0.05 | NR | NR | NR | NR | NR
Antitussive (opiates) vs. Placebo | Matthys, 1983^125^ | Cough intensity on scale of 0-10: Codeine=4.6 (SD 1.5) (baseline), 4.5 (SD 1.6) (after 8 hr) Placebo=6.5 (SD 2.0) (baseline), 6.8 (SD 2.7) (after 8 hr) p<0.0001 | Nocturnal night counts per hr: Codeine=9.8 (SD 7.5) (baseline), 4.9 (SD 4.3) (after 8 hr) Placebo=9.6 (SD 8.1) (baseline), 15.2 (SD 11.6) (after 8 hr) p<0.0001 | NR | NR | NR | NR | Patient preference (% patients rating) Codeine=12.5% (Best), 12.5% (Worst) Placebo=0% (Best), 81.25% (Worst) p<0.001
Antitussive (opiates) vs. Placebo | Smith, 2006^96^ | Mean day cough symptom score (0-5) after 10d: Codeine=2.8 (SD 1.0) Placebo=2.7 (SD 0.6) P=0.59 | Median day cough frequency (time spent coughing in coughs/hour) after 10d: Codeine=10.7 (IQR, 6.2 to14.6) Placebo=11.1 (IQR, 7.7 to 16.4) | NR | NR | Log median tussigenic citric acid cough challenge test (C2) after 10d: Codeine=-0.90 (IQR, -1.2 to -0.6) Placebo=-0.60 (IQR, -1.5 to -0.9) | Two subjects complained of drowsiness, one on both study days, the other on the codeine study day | NR
Antitussive (opiates) vs. Placebo | Morice, 2007^80^ | Mean difference of daily score (0-9) after 28 days: Morphine=3.45 (SD 1.76) Placebo=4.98 (SD 1.68) | NR | NR | LCQ change in score after 28 days: Morphine=15.5 (SD 2.7) Placebo=13.5 (SD 2.7) p<0.02 | Mean tussigenic citric acid cough challenge test (C2) after 28 days: Morphine=220 (SD 344) Placebo=127 (SD 160) | Morphine was well tolerated and no patient dropped out because of adverse events. The most common side effects noted were constipation (40%) and drowsiness (25%) | NR
Antitussive (other) vs. Antitussive (other) | Cass, 1956^112^ | Mean daily cough score (0-4) over the 10 days: Dextromethorphan (20 mg)=0.92 Dextromethorphan (10 mg)=0.86 | NR | NR | NR | NR | NR | NR
Antitussive (other) vs. Antitussive (other) | Ruhle, 1984^131^ | Mean patient score (1-5) 8 hr after dose: Glaucine=2.9 Dextromethorphan=3.1 | Nocturnal number of coughs after three treatments: Glaucine=511 Dextromethorphan=540 | NR | NR | NR | Incidence of side effects after three treatments: Glaucine=1 Dextromethorphan=8 p<0.05 | NR
Antitussive (other) vs. Antitussive (other) | Del Donno, 1994^115^ | Reduction in mean VAS score of morning cough troubleness: Moguisteine=47.6 (SD 25.1) (baseline), 24.3 (SD 19.3) (2 days) Dextromethorphan=47.2 (SD 23.9) (baseline), 28.0 (SD 20.8) (2 days) | Percentage reduction in number of coughs during 6-hr period after last dose vs. at baseline: Moguisteine=29.4% Dextromethorphan=30% | NR | NR | NR | Reduction in mean VAS score of sleep disturbance: Moguisteine=48.0 (SD 29.2) (baseline), 30.1 (SD 27.8) (2 days) Dextromethorphan=44.5 (SD 26.4) (baseline), 27.2 (SD 22.5) (2 days) | NR
Antitussive (other) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Levocloperastine=2.68 (baseline), 1.2 (end of treatment mean 9.5 days) Levodropropizine=2.56 (baseline), 0.32 (end of treatment mean 9.3 days) | Mean score between 0-4: Levocloperastine=2.60 (baseline), 0.12 (end of treatment mean 9.5 days) Levodropropizine=2.28 (baseline), 0.36 (end of treatment mean 9.3 days) | Mean score between 0-4: Levocloperastine=2.5 (baseline), 0.12 (end of treatment mean 9.5 days) Levodropropizine=1.84 (baseline), 0.12 (end of treatment mean 9.3 days) p<0.05 at baseline | NR | NR | NR | NR
Antitussive (other) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Levocloperastine=2.60 (baseline), 0.17 (end of treatment mean 9.0 days) Levodropropizine=2.43 (baseline), 0.67 (end of treatment mean 8.5 days) | Mean score between 0-4: Levocloperastine=2.67 (baseline), 0.17 (end of treatment mean 9.0 days) Levodropropizine=2.67 (baseline), 0.83 (end of treatment mean 8.5 days) | Mean score between 0-4: Levocloperastine=2.07 (baseline), 0.07 (end of treatment mean 9.0 days) Levodropropizine=1.80 (baseline), 0.40 (end of treatment mean 8.5 days) p<0.05 | NR | NR | NR | NR
Antitussive (other) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Levocloperastine=2.45 (baseline), 0.10 (end of treatment mean 9.2 days) Levodropropizine=2.50 (baseline), 0.65 (end of treatment mean 9.2 days) | Mean score between 0-4: Levocloperastine=2.70 (baseline), 0.10 (end of treatment mean 9.2 days) Levodropropizine=2.20 (baseline), 0.75 (end of treatment mean 9.2 days) | Mean score between 0-4: Levocloperastine=2.10 (baseline), 0.10 (end of treatment mean 9.2 days) Levodropropizine=1.75 (baseline), 0.30 (end of treatment mean 9.2 days) | NR | NR | NR | NR
Antitussive (other) vs. Antitussive (other) | Aliprandi, 2004^108^ | Mean score between 0-4: Levocloperastine=2.65 (baseline), 0.15 (end of treatment mean 13.3 days) DL-cloperastine=2.58 (baseline), 0.72 (end of treatment mean 13.6 days) p<0.001 | Mean score between 0-4: Levocloperastine=2.60 (baseline), 0.13 (end of treatment mean 13.3 days) DL-cloperastine=2.48 (baseline), 0.62 (end of treatment mean 13.6 days) p<0.001 | Mean score between 0-4: Levocloperastine=2.15 (baseline), 0.05 (end of treatment mean 13.3 days) DL-cloperastine=2.15 (baseline), 0.48 (end of treatment mean 13.6 days) p<0.001 | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Cass, 1953^110^ | Mean intensity of cough after 5 d of treatment: Dextromethorphan (4 mg)=1,38 Placebo=1.52 | NR | NR | NR | NR | No. of patients recorded as having side effect during 5 d study period: Dextromethorphan (4 mg)=19 Placebo=17 | NR
Antitussive (other) vs. Placebo | Cass, 1954^111^ | Intensity of cough (based on Likert scale 0-4) after 35 d: Dextromethorphan=1.28 Placebo=1.49 | NR | NR | NR | NR | No. of patients with side effects after 35 d: Nausea: Dex=3, placebo=3 Vomiting: Dex=0, placebo=0 Constipation: Dex=3, placebo=0 Drowsiness: Dex=1, placebo=2 Sleepiness: Dex=1, placebo=0 | NR
Antitussive (other) vs. Placebo | Cass, 1956^112^ | Mean daily cough score (0-4) over the 10 days: Dextromethorphan=0.86 Placebo=1.15 | NR | NR | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Vakil, 1966^137^ | NR | Average of 3 hourly cough counts: Pipazethate=53.2 Placebo=52.6 | NR | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Wojcicki, 1975^142^ | No. of patients with marked or moderate relief: Duopect=28/32 Placebo=3/32 p<0.05 | NR | NR | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Dierckx, 1981^116^ | Patient judgment on efficacy of treatment 8 hr after single dose (1-5): Glaucine=2.76 Placebo=2.66 | Nocturnal cough counts 8 hr after single treatment Glaucine=241.8 (SEM 29.9) Placebo=269.3 (SEM 31.3) P<0.05 | NR | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Matthys, 1983^125^ | Cough intensity on scale of 0-10: Dextromethorphan=4.4 (SD 1.5) (baseline), 2.9 (SD 1.9) (after 8 hr) Placebo=6.5 (SD 2.0) (baseline), 6.8 (SD 2.7) (after 8 hr) p<0.0001 | Nocturnal night counts per hr: Dextromethorphan=9.5 (SD 6.9) (baseline), 3.4 (SD 3.4) (after 8 hr) Placebo=9.6 (SD 8.1) (baseline), 15.2 (SD 11.6) (after 8 hr) p<0.0001 | NR | NR | NR | NR | Patient preference (% patients rating) Dextromethorphan=87.5% (Best), 6.25% (Worst) Placebo=0% (Best), 81.25% (Worst) p<0.001
Antitussive (other) vs. Placebo | Ruhle, 1984^131^ | Mean patient score (1-5) 8 hr after dose: Dextromethorphan=3.1 Placebo=2.9 | Nocturnal number of coughs after three treatments: Dextromethorphan=540 Placebo=689 | NR | NR | NR | Incidence of side effects after three treatments: Dextromethorphan=8 Placebo=2 p<0.05 | NR
Antitussive (other) vs. Placebo | Ruhle, 1984^131^ | Mean patient score (1-5) 8 hr after dose: Glaucine=2.9 Placebo=2.9 | Nocturnal number of coughs after three treatments: Glaucine=511 Placebo=689 p<0.05 | NR | NR | NR | Incidence of side effects after three treatments: Glaucine=1 Placebo=2 | NR
Antitussive (other) vs. Placebo | Aversa, 1993^109^ | NR | Reduction in number of coughs in the interval 8-10am on day four vs. day one: Moguisteine: 42% Placebo: 14% p=0.028 | NR | NR | NR | NR | NR
Antitussive (other) vs. Placebo | Ramsay, 2008^129^ | Mean VAS score (1-5) at day 5: Dextromethorphan=1.39 Placebo=1.66 Difference=-0.26 (CI -0.99 to 0.46) | NR | NR | LCQ (physical): Dextromethorphan=43.9 Placebo=43.7 LCQ (psychological): Dextromethorphan=42.1 Placebo=42.1 LCQ (social): Dextromethorphan=23.6 Placebo=23.2 | Mean tussigenic citric acid cough challenge test (C2) 1 hr post dose: Dextromethorphan=3.04 Placebo=1.71 p<0.05 | Mean VAS score (or sleep disturbance (1-5) at day 5: Dextromethorphan=0.75 Placebo=0.75 | NR
Antitussive (other) vs. Placebo | Mukaida, 2011^127^ | VAS score for cough intensity: Bakumondoto vs. Placebo, p=0.055, 0.387 in two treatment periods | VAS score for cough frequency: Bakumondoto vs. Placebo=0.007, 0.055 in two treatment periods | NR | NR | NR | NR | NR
Antitussive (other) vs. Protussive (expectorants) | Wojcicki, 1975^142^ | No. of patients with marked or moderate relief: Duopect=28/32 Glycerol=13/32 p<0.05 | NR | NR | NR | NR | NR | NR
Antitussive (other) vs. Protussive (expectorants) | Matts, 1977^126^ | NR | NR | NR | NR | NR | NR | Patient preference for treatment: Diphenhydramine=36/49 patients Guaifenesin=13/49 patients
Bronchodilator vs. Bronchodilator | Wei, 2010^141^ | Mean cough symptom score: Diprophylline=3.0 (SD 0.81) (baseline), 1.49 (SD 0.44) (4 wk) Methoxyphenamine=3.0 (SD 0.85) (baseline), 1.48 (SD 0.51) (4 wk) | No. of patients with cough resolution at 16 wk: Diprophylline=72.6% Methoxyphenamin=74.1% | NR | Mean LCQ: Diprophylline=14.27 (SD 3.16) (baseline), 5.48 (SD 3.58) (4 wk) Methoxyphenamine=14.32 (SD 3.19) (baseline), 5.58 (SD 3.23) (4 wk) | NR | NR | NR
Corticosteroid vs. Placebo | Chaudhuri, 2004^113^ | Change in VAS scale (0-10) after 14 d: Fluticasone compared with before and after placebo (difference of differences, 1.0; 95% CI, 0.4 to 1.5; P<0.001) Mean percentage change in VAS was 22.3% (95% CI, -3.5% to 48.2%) | NR | NR | NR | NR | NR | NR
Corticosteroid vs. Placebo | Ribeiro, 2007^93^ | No. of patients with no cough after 2 wk: Beclomethasone=35/44 Placebo=4/20 p<0.05 | No. of patients with resolution of cough after 2 wk: Beclomethasone=34/44 Placebo=3/20 p<0.05 | NR | NR | NR | No. of patients with no sleep disturbance after 2 wk: Beclomethasone=42/44 Placebo=19/20 | NR
Protussive (expectorants) vs. Placebo | Wojcicki, 1975^142^ | No. of patients with marked or moderate relief: Glycerol=13/32 Placebo=3/32 p<0.05 | NR | NR | NR | NR | NR | NR
Protussive (expectorants) vs. Placebo | Parvez, 1996^128^ | Median change in average cough intensity on day 14: Guaifenesin=-0.03 (range -0.22 to 0.19) Placebo=-0.03 (range -0.4 to 0.1) | Median change in 3-hr cough count on day 14: Guaifenesin=-27.5 (range -219 to 157) Placebo=-37 (range -155 to 350) | NR | NR | NR | NR | NR
Protussive (mucolytic) vs. Placebo | Jackson, 1984^122^ | Patient-reported score 0-3: N-acetylcysteine=1.75 (SD 0.79) (baseline), 1.38 (SD 0.76) (1 mo), 1.3 (SD 0.85) (2 mo), 1.23 (SD 0.74) (3 mo) Placebo=1.98 (SD 0.77) (baseline), 1.48 (SD 0.81) (1 mo), 1.5 (SD 0.75) (2 mo), 1.5 (SD 0.83) (3 mo) P<0.01 | NR | NR | NR | NR | NR | Physician-reported global assessment over 3 mo period: N-acetylcysteine=85% patients/change Placebo=68% patients/change p=0.063
Protussive (mucolytic) vs. Placebo | Guyatt, 1987^120^ | Cough interfering with daily activities (1-7 scale): Ambroxol=4.67 (baseline), 4.18 (4 wk) Placebo=4.76 (baseline), 5.37 (4 wk) Net Benefit=-0.09 (CI -0.67 to 0.50) | NR | NR | NR | NR | NR | NR
Protussive (mucolytic) vs. Placebo | Dueholdm, 1992^118^ | Intensity of coughing, median change from baseline at 16 wk: N-acetylcysteine=0.02 (CI -0.52 to 0.47) Placebo=-1.03 (CI -1.31 to 0.12) p<0.05 | NR | NR | VAS score between 0-10 on well-being, median change from baseline at 16 wk: N-acetylcysteine=0.14 (CI -0.47 to 0.56) Placebo=-0.02 (CI -0.82 to 1.21) | NR | NR | Morning dyspnea, median change from baseline at 16 wk: N-acetylcysteine=0.48 (CI -0.03 to 1.13) Placebo=-0.01 (CI -0.29 to 0.31) Exercise dyspnea, median change from baseline at 16 wk: N-acetylcysteine=0.10 (CI -0.34 to 0.65) Placebo=-0.45 (CI -1.24 to 0.22)
Protussive (mucolytic) vs. Placebo | Parvez, 1996^128^ | Median change in average cough intensity on day 14: Bromhexine=0.15 (SD 10.00) Placebo=-3.21 (SD 9.7) | Median change in 3-hr cough count on day 14: Bromhexine=-9.11 (SD 67.5) Placebo=-44 (SD 94.1) | NR | NR | NR | NR | NR
Protussive (mucolytic) vs. Protussive (mucolytic) | Clarke, 1979^114^ | NR | Mean number of coughs, 6 hr after inhalation: 2-mercapto-ethane sulphonate=99 (SD 154) hypertonic saline=91 (SD 116) | NR | NR | NR | NR | NR
Protussive (nonpharmacological) vs. Protussive (nonpharmacological) | van Hengstum, 1988^139^ | NR | NR | NR | NR | NR | NR | Retention after therapy: Positive expiratory pressure=70 (SD 14) Forced expiration technique=46 (SD 15) p<0.02

CI = confidence interval; d = day(s); hr = hour(s); LCQ = Leicester Cough Questionnaire; mo = month(s); No. = Number; NR = not reported; NS = not statistically significant; SD = standard deviation; SEM = standard error of the mean; VAS = visual analog scale; wk = week(s)

a If p value is not listed, the comparison was not statistically significant (p ≥ 0.05).

#### Studies Involving Opiate Antitussives

Among the studies reviewed, we found 29 comparisons within 17 studies involving opiate antitussives: 11 comparisons were with placebo,80,96,103,110-112,116,125,132,133,135 2 comparisons were of different doses of the same opiates,132,133 2 comparisons were with anesthetic antitussives,117,135 and 10 comparisons were with nonopioid/nonanesthetic antitussives.34,108,110-112,116,119,124,125 In the 11 comparisons of opiates with placebo,80,96,103,110-112,116,125,132,133,135 opiates were more effective for improving cough frequency, cough severity, and/or quality of life (LCQ) in 8 of the studies.80,103,110-112,116,125,133 The effective regimens in these studies were codeine 7.5–60 mg or morphine 5 mg. In one study, the opioid morphine resulted in significant rates of constipation and drowsiness but was not discontinued due to tolerability issues.80 No one opioid was found to be superior to another in within-class comparisons, although codeine had a dose-response improvement in cough severity and frequency in a study comparing the following doses: 7.5 mg, 15 mg, 30 mg and 60 mg.133 A study of another opiate, viminol, found a higher dose (140 mg) to be effective at reducing cough severity, but a lower dose (70 mg) was no different from placebo.132

When compared with anesthetic antitussives, opiates were not more effective for cough in the two studies making this comparison.117,135 Opiates (only codeine derivatives in these studies) were compared with a variety of nonopioid/nonanesthetic antitussives. Codeine had comparable efficacy for reducing cough frequency, but was less effective than dextromethorphan for improving cough severity in one study.125 In another study, the two agents were comparable for cough severity.112 Two studies showed codeine 15–17 mg 3–4 times a day was more effective at reducing cough severity than low-dose dextromethorphan (4-6 mg 3–4 times a day).110,111 Two studies comparing codeine with glaucine reported conflicting results; one noted significantly better improvement in cough severity and frequency with glaucine,119 while the other noted no significant differences in cough frequency over 8 hours of followup; codeine did result in lower frequency of cough over the final 2 hours of the 8-hour duration.116 Codeine or dihydrocodeine were similar in effectiveness for cough to moguisteine,34 levodropropizine,124 and levocloperastine108 in studies making these comparisons.

In terms of tolerability, 2 of 39 patients taking codeine 30 mg in one study discontinued the study medication due to side effects: dry mouth and asthenia in one patient, nausea in the other patient.34 In another study, the percentage of patients experiencing somnolence while taking dihydrocodeine was significantly higher (22%) than in in the group receiving levodropropizine (8%).124 In two studies, side effects of nausea, constipation, and/or drowsiness were more frequent with codeine than with dextromethorphan.110,111

#### Studies Involving Anesthetic Antitussives

Anesthetic antitussives were examined in three studies resulting in four comparisons: one comparison was with placebo,135 two were with opioids,117,135 and one study compared two anesthetic antitussives.134 Benzonatate was not superior to placebo in the one study making this comparison.135 Clophedianol and benzonatate were not more effective for cough than opiates in the two studies making these comparisons.117,135 The two anesthetic antitussives, benzonatate and Becantyl^®^ (sodium 2.6 ditertiarybutylnaphtalene monosulphonate; also named Becantex^®^ or L.1633), had comparable effects on cough severity in one study.134

#### Studies Involving Other Antitussives

We found 31 comparisons in 21 studies involving other (i.e., nonopioid/nonanesthetic) antitussives: 12 were comparisons with placebo,109-112,116,125,127,129,131,137,142 7 were comparisons between 2 nonopioid/nonanesthetic antitussives,108,112,115,131 1 was a comparison of a combined antitussive/expectorant with the expectorant alone,142 and 10 were comparisons with opioids34,108,110-112,116,119,124,125 (see the section on “Studies Involving Opiate Antitussives” for a summary of these studies). Six studies compared dextromethorphan with placebo,110-112,125,129,131 with 5 of these supporting the efficacy of dextromethorphan for treatment of cough.110-112,125,129 In one study,125 dextromethorphan 20 mg twice a day was more effective than placebo for reducing both cough frequency and severity. In another study,129 dextromethorphan 30 mg three times a day was more effective than placebo at reducing cough in response to citric acid tussigenic challenge but not for cough severity, sleep disturbance, or cough-specific quality of life (LCQ). In three studies, dextromethorphan 4–20 mg 3–4 times a day were better than placebo for improvement of cough severity.110-112 In the one negative study,131 dextromethorphan 30 mg once was no better than placebo for impacting cough frequency or severity. A study examining glaucine 30 mg compared with placebo noted improvements in a 6-hour subset of 8-hour nocturnal cough frequency, but not in the full 8-hour duration of followup.131 Another study of glaucine 30 mg noted lower cough frequency than placebo after 4 hours.116 A Chinese herbal medicine consisting of extracts from six crude herbs called bakumondoto (3 g of powder before each meal) reduced cough severity and frequency compared with no treatment control over 8 weeks by participant self-report in diaries and on a visual analog scale.127 Moguistene 200 mg 3 times a day was more effective than placebo for reducing cough frequency over 4 days.109 Pipazethate 20 mg did not reduce cough frequency compared with placebo.137

In seven studies, none of the “other” antitussives was found to be superior to another in comparisons made among them,108,115,131 nor were different doses of the same agent.112

One study compared the combination antitussive/expectorant Duopect^®^ (narcotine/glycerol) 17 mg/120 mg 3 times a day, narcotine 17 mg, glycerol 120 mg 3 times a day, and placebo. More participants taking Duopect or narcotine than glycerol alone or placebo reported moderate to marked improvement in cough severity (n=28 vs. 24 vs. 13 vs. 3, respectively, of 32 patients in each arm, p<0.01 for Duopect and narcotine vs. glycerol and placebo).142 Expectoration was “easier and freer” in a higher percentage of patients taking Duopect or glycerol than narcotine or placebo. In a multi-arm study, dextromethorphan 10 mg and 20 mg were similarly better than placebo for improvement of cough severity.112

#### Studies Involving Protussives

There were 10 comparisons involving protussives: two were comparisons of an expectorant with placebo,128,142 two were comparisons of an expectorant with an ‘other’ antitussive,126,142 four were comparisons of a mucolytic with placebo,118,120,122,128 and one study compared a mucolytic with another mucolytic.114 Compared with placebo, the expectorant bromhexine did not reduce cough frequency in one study.128 In another study, guaifenesin reduced cough intensity (on 1 of 4 days that were analyzed over 2 weeks), increase sputum volume (on 1 of the 4 days), and improved subjective “ease of expectoration” in a subgroup of high-volume sputum patients.128 Another study compared the combination antitussive/expectorant Duopect (narcotine/glycerol) 17 mg/120 mg 3 times a day, narcotine 17 mg, glycerol 120 mg 3 times a day, and placebo. More participants taking Duopect or narcotine than glycerol alone or placebo reported moderate to marked improvement in cough severity (n=28 vs. 24 vs. 13 vs. 3, respectively, of 32 patients in each arm, p<0.01 for Duopect and narcotine vs. glycerol and placebo).142 Expectoration was “easier and freer” in a higher percentage of patients taking Duopect or glycerol than narcotine or placebo. The following regimens did not improve cough frequency, severity, and/or quality of life compared with placebo: N-acetylcysteine 200 mg 3 times a day,122 N-acetylcysteine 4 mg inhaled via metered-dose inhaler 4 times a day,118 bromhexine 16 mg 4 times a day.128 or ambroxol 60 mg twice a day.120 In a comparison of inhaled aerosols, 2-mercapto-ethane sulfonate was not more effective than hypertonic saline at improving tracheobronchial clearance.114

#### Studies Involving Nonantitussive and Nonprotussive Pharmacotherapies

We identified four studies examining the effect of antihistamine medication on cough123,130,136,138 Two of these studies were in children130,138 and are discussed separately below. In the adult studies, one compared diphenhydramine 50 mg with diphenhydramine 25 mg to placebo, all preparations scheduled 4 times a day.123 The two doses of diphenhydramine did not differ in efficacy for cough frequency, but both doses were superior to placebo. Higher dose diphenhydramine resulted in a greater frequency of drowsiness than the lower dose, which was comparable with placebo. In a placebo-controlled study,136 loratadine 10 mg reduced the number of coughs following tussigenic challenge with ultrasonically nebulised distilled water in patients with nasal disease or unexplained chronic cough but not in normal patients.

One study examined the effect of the antibiotic erythromycin at a dose of 250 mg once a day and found no difference in cough severity, cough frequency, cough-specific quality of life or response to tussigenic challenge compared with placebo.143 A study compared ipratroprium bromide 20 mcg inhaler, 4 puffs 4 times a day, with placebo and found improvements in cough severity and dyspnea associated with cough.121 A study comparing two bronchodilators (diprophylline 200 mg 3 times a day vs. methoxyphenamine 2 capsules 3 times a day) did not find differences in their effects on cough frequency or cough-specific quality of life.141 Two studies evaluated inhaled corticosteroids in patients with chronic cough of unknown etiology and found that cough severity was reduced113 or cough more frequently resolved93 compared with placebo.

#### Studies Involving Nonpharmacological Therapies

We identified only two studies that evaluated the comparative safety and effectiveness of nonpharmacological interventions for chronic cough.139,140 Van Hengstum et al.139 compared 20 minutes of positive expiratory pressure (PEP) physiotherapy with 30 minutes of a forced expiratory technique (FET) and no treatment using a randomized crossover trial involving eight adult patients (age range, 48–73 years) with chronic bronchitis. FET was found to be more effective than either PEP or no treatment in enhancing the primary outcome of tracheobronchial clearance, but there was no evidence that either treatment was effective in improving cough frequency or severity. This study was rated as fair quality because of the small sample size and nonblinded study design. Applicability is limited due to incomplete reporting of the interventions and the use of short-term, surrogate outcomes.

The second study was a randomized, placebo-controlled trial that compared speech pathology management with placebo among 87 adult patients with refractory chronic cough of at least 2 months in duration.140 Patients in both study arms participated in four individual 30-minute intervention sessions with a speech pathologist with experience in treating voice disorders. The active intervention included targeted education and training in strategies to reduce cough and laryngeal irritation. The placebo intervention consisted of healthy lifestyle education, stress management, exercise, and diet. Patients in the intervention arm demonstrated greater reduction in cough (p=0.003) and limitation of symptoms on everyday activity (p=0.011) symptom scores relative to those in the placebo arm. The active treatment was also associated with greater reduction in breathing, voice, and upper airways symptom scores relative to the placebo intervention. This study was rated as fair quality because of the single-blind study design and the lack of a validated outcome measure. Applicability is limited by an intervention that requires a level of training or proficiency that is not widely available.

#### Studies Involving Children

Three studies addressed the treatment of chronic cough in children less than 14 years of age. Two of these evaluated ketotifen, an H1-antihistimine and mast-cell stabilizer.130,138 In the United States, ketotifen is currently not available in oral form but is available as an eye drop for allergic conjunctivitis. The oral form is, however, available internationally, including from Canada. Both studies were RCTs of ketotifen versus placebo for children with chronic cough and/or wheeze. One evaluated 113 children between 6 and 36 months of age over 16 weeks,138 and the other 214 children between 2 and 6 years of age over 12 weeks.130 In the study of younger children, ketotifen was not more efficacious than placebo. However, the study of older children reported that the number of exacerbations of cough and wheeze lasting 3 or more days was reduced in the group treated with ketotifen compared with placebo. In addition, there was a decrease in the proportion of children taking beta-agonists and methylxanthines. The study of younger children was rated as good quality. The study of older children was rated fair because there was no allocation concealment, the primary outcome measure was unclear with multiple comparisons, and the study was industry funded. These two studies have low applicability to the management of children with chronic cough. In both studies, all subjects likely had asthma as their source of chronic cough. These studies were published over 20 years ago (in 1989 and 1992). The management of asthma has significantly changed since these studies were conducted, with greater emphasis on the role of controller medicines (e.g., inhaled corticosteroids, leukotriene inhibitors) to reduce the chronic symptoms associated with poorly controlled asthma. It is unclear whether findings regarding ketotifen are generalizable to the other available medications in its class.

The third study was a randomized, placebo-controlled trial of an antibiotic, amoxicillin clavulanate, in children with more than 3 weeks of wet cough.144 Children were randomized to 14 days of antibiotic or placebo, and outcomes were measured with a cough diary using the verbal category descriptive score. The primary outcome was cough resolution, based on at least 75 percent reduction in cough score on average during the 2 days following treatment or 3 days within a the trial period. Fifty children were enrolled. The mean age in the treatment group was 1.75 years (range, 0.9 to 4.6 years) and 2.8 years (range, 0.95 to 5.25 years) in the control group. Cough resolution was 48 percent in the treatment group and 16 percent in the placebo group (p=0.0016), with a number needed to treat of 4. This study was rated as good quality, and although it had a small sample size and the description of diagnostic evaluation of cough was minimal, it otherwise had good applicability.

#### Quantitative Synthesis

The heterogeneity of the included studies in terms of the interventions and comparators (Figure 3), combined with the lack of three or more studies reporting the same outcome where there were multiple comparisons (Table 8), precluded us from performing meta-analyses on almost all outcomes.

We were, however, able to evaluate the relative effects on cough severity for four classes of treatments for chronic cough: antitussive opiates, antitussive dextromethorphan, antitussive moguisteine, and protussive mucolytics. Thirteen studies reported results for cough severity, but two of these116,131 did not provide sufficient information to estimate effect sizes. Of the remaining 11 studies (n=396 patients), 4 provided information on mucolytics, 3 provided information on dextromethorphan, 2 provided information on moguisteine, and 4 provided information on opiates. Most of the 11 studies compared the treatment with placebo,34,80,115,118,120,122,125,128,129,132,135 but one compared opiates with dextromethorphan and placebo.125 Methods used to measure cough severity differed widely amongst the studies, from studies looking at the proportion of patients receiving good or excellent cough relief after treatment,134 to those evaluating a mean cough severity score using various Likert scores or VAS instruments,34,80,115,120,122,129,132 to those measuring the median or mean change in intensity of cough.118,125,128 Because each study used a different measure of severity, we converted all results to effect sizes (standardized mean differences). Relative to placebo, the effect of dextromethorphan on cough severity was 0.54 (95% confidence interval [CI], 0.27 to 0.80; p=0.0008), the effect of opiates was 0.63 (95% CI, 0.40 to 0.86; p<0.0001), the effect of moguisteine was 0.62 (95% CI, 0.04 to 1.16, p=0.0366), and the effect of mucolytics was 0.14 (95% CI -0.20 to 0.49; p=0.384; Figure 4). The studies showed heterogeneity (p=0.0023). The effects of dextromethorphan, moguisteine, and opiates compared with placebo on cough severity support a benefit of these therapies, but the evidence is insufficient to determine relative benefit among these therapies.

Figure 4 Meta-analysis of data on cough severity

This figure is a forest plot showing the relative effects on cough severity of antitussive opiates, the antitussive dextromethorphan, and protussive mucolytics. Effect sizes relative to placebo (with 95% CIs) are: for dextromethorphan, 0.54 (95% CI, 0.27 to 0.80; p=0.0008); for opiates, 0.63 (95% CI, 0.40 to 0.86; p<0.0001); for moguisteine, 0.62 (95% CI, 0.04 to 1.16, p=0.0366); and for mucolytics, 0.14 (95% CI -0.20 to 0.49; p=0.384). The studies showed heterogeneity (p=0.0023). The effects of dextromethorphan, moguisteine, and opiates compared with placebo on cough severity support a benefit of these therapies, but the evidence is insufficient to determine relative benefit among these therapies.

We performed a similar meta-analysis for cough frequency, including 7 studies (n=700 patients).34,109,115,116,125,133,135 Relative to placebo, the effect of dextromethorphan on cough frequency was 0.40 (95% CI, 0.18 to 0.85; p=0.0248), the effect of codeine was 0.57 (95% CI, 0.36 to 0.91; p=0.0260), and the effect of moguisteine was 0.60 (95% CI, 0.31 to 1.17, p=0.1117; Figure 5). The studies showed significant heterogeneity (p=0.0231). The effects of dextromethorphan and codeine compared with placebo on cough frequency support a benefit of these therapies, although the estimates are too imprecise to determine if one is superior to another. The effect of moguisteine was too imprecise to draw conclusions about is efficacy.

Figure 5 Meta-analysis of data on cough frequency

This figure is a forest plot showing the relative effects on cough frequency of antitussive opiates, the antitussive dextromethorphan, and protussive mucolytics. Effect sizes relative to placebo (with 95% CIs) are: for dextromethorphan, 0.40 (95% CI, 0.18 to 0.85; p=0.0248); for codeine, 0.57 (95% CI, 0.36 to 0.91; p=0.0260); and for moguisteine, 0.60 (95% CI, 0.31 to 1.17, p=0.1117). The studies showed significant heterogeneity (p=0.0231). The effects of dextromethorphan and codeine compared with placebo on cough frequency support a benefit of these therapies.