# References

1 Centers for Disease Control and Prevention. National Ambulatory Medical Care Survey: 2008 Summary Tables. www.cdc.gov/nchs/ahcd.htm.
2 Chang AB, Glomb WB. Guidelines for evaluating chronic cough in pediatrics: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):260S-83S. [pmid: 16428719].
3 Pratter MR. Overview of common causes of chronic cough: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):59S-62S. [pmid: 16428693].
4 Irwin RS, Corrao WM, Pratter MR. Chronic persistent cough in the adult: the spectrum and frequency of causes and successful outcome of specific therapy. Am Rev Respir Dis. 1981;123(4 Pt 1):413-7. [pmid: 7224353].
5 Irwin RS, Curley FJ, French CL. Chronic cough. The spectrum and frequency of causes, key components of the diagnostic evaluation, and outcome of specific therapy. Am Rev Respir Dis. 1990;141(3):640-7. [pmid: 2178528].
6 Chung KF, Pavord ID. Prevalence, pathogenesis, and causes of chronic cough. Lancet. 2008;371(9621):1364-74. [pmid: 18424325].
7 Irwin RS, Curley FJ. The treatment of cough. A comprehensive review. Chest. 1991;99(6):1477-84. [pmid: 2036833].
8 French CL, Irwin RS, Curley FJ, et al. Impact of chronic cough on quality of life. Arch Intern Med. 1998;158(15):1657-61. [pmid: 9701100].
9 Holinger LD, Sanders AD. Chronic cough in infants and children: an update. Laryngoscope. 1991;101(6 Pt 1):596-605. [pmid: 2041439].
10 Pratter MR, Bartter T, Akers S, et al. An algorithmic approach to chronic cough. Ann Intern Med. 1993;119(10):977-83. [pmid: 8214994].
11 Smyrnios NA, Irwin RS, Curley FJ. Chronic cough with a history of excessive sputum production. The spectrum and frequency of causes, key components of the diagnostic evaluation, and outcome of specific therapy. Chest. 1995;108(4):991-7. [pmid: 7555175].
12 Mello CJ, Irwin RS, Curley FJ. Predictive values of the character, timing, and complications of chronic cough in diagnosing its cause. Arch Intern Med. 1996;156(9):997-1003. [pmid: 8624180].
13 Irwin RS, Baumann MH, Bolser DC, et al. Diagnosis and management of cough executive summary: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):1S-23S. [pmid: 16428686].
14 Smyth RL. Research with children. Paediatric practice needs better evidence—gained in collaboration with parents and children. Br Med J. 2001;322(7299):1377-8. [pmid: 11397728].
15 Sinaiko AR, Daniels SR. The use of short-acting nifedipine in children with hypertension: another example of the need for comprehensive drug testing in children. J Pediatr. 2001;139(1):7-9. [pmid: 11445783].
16 Schroeder K, Fahey T. Should we advise parents to administer over the counter cough medicines for acute cough? Systematic review of randomised controlled trials. Arch Dis Child. 2002;86(3):170-5. [pmid: 11861232].
17 Paul IM, Yoder KE, Crowell KR, et al. Effect of dextromethorphan, diphenhydramine, and placebo on nocturnal cough and sleep quality for coughing children and their parents. Pediatrics. 2004;114(1):e85-90. [pmid: 15231978].
18 Kelly LF. Pediatric cough and cold preparations. Pediatr Rev. 2004;25(4):115-23. [pmid: 15060179].
19 Hestand HE, Teske DW. Diphenhydramine hydrochloride intoxication. J Pediatr. 1977;90(6):1017-8. [pmid: 859051].
20 Irwin RS. Introduction to the diagnosis and management of cough: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):25S-7S. [pmid: 16428688].
21 Molassiotis A, Bryan G, Caress A, et al. Pharmacological and non-pharmacological interventions for cough in adults with respiratory and non-respiratory diseases: A systematic review of the literature. Respir Med. 2010;104(7):934-44. [pmid: 20385478].
22 Pratter MR, Brightling CE, Boulet LP, et al. An empiric integrative approach to the management of cough: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):222S-31S. [pmid: 16428715].
23 Finnish Medical Society Duodecim. Chronic cough in a child. EBM Guidelines Evidence-Based Medicine [Internet]. Helsinki, Finland. Wiley Interscience John Wiley & Sons. 2007. nowww.guideline.gov/content.aspx?id=12798.
24 Gibson PG, Vertigan AE. Speech pathology for chronic cough: a new approach. Pulm Pharmacol Ther. 2009;22(2):159-62. [pmid: 19061964].
25 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.
26 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=558&pageaction=displayproduct.
27 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
28 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: A revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
29 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
30 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
31 Archer LN, Simpson H. Night cough counts and diary card scores in asthma. Arch Dis Child. 1985;60(5):473-4. [pmid: 4015154].
32 Au DH, Blough DK, Kirchdoerfer L, et al. Development of a quantifiable symptom assessment tool for patients with chronic bronchitis: the Chronic Bronchitis Symptoms Assessment Scale. COPD. 2005;2(2):209-16. [pmid: 17136947].
33 Baiardini I, Braido F, Fassio O, et al. A new tool to assess and monitor the burden of chronic cough on quality of life: Chronic Cough Impact Questionnaire. Allergy. 2005;60(4):482-8. [pmid: 15727580].
34 Barnabe R, Berni F, Clini V, et al. The efficacy and safety of moguisteine in comparison with codeine phosphate in patients with chronic cough. Monaldi Arch Chest Dis. 1995;50(2):93-7. [pmid: 7613554].
35 Barry SJ, Dane AD, Morice AH, et al. The automatic recognition and counting of cough. Cough. 2006;2:8. [pmid: 17007636].
36 Birring SS, Fleming T, Matos S, et al. The Leicester Cough Monitor: preliminary validation of an automated cough detection system in chronic cough. Eur Respir J. 2008;31(5):1013-8. [pmid: 18184683].
37 Birring SS, Matos S, Patel RB, et al. Cough frequency, cough sensitivity and health status in patients with chronic cough. Respir Med. 2006;100(6):1105-9. [pmid: 16266801].
38 Birring SS, Prudon B, Carr AJ, et al. Development of a symptom specific health status measure for patients with chronic cough: Leicester Cough Questionnaire (LCQ). Thorax. 2003;58(4):339-43. [pmid: 12668799].
39 Braido F, Baiardini I, Tarantini F, et al. Chronic cough and QoL in allergic and respiratory diseases measured by a new specific validated tool-CCIQ. J Investig Allergol Clin Immunol. 2006;16(2):110-6. [pmid: 16689184].
40 Chang AB, Newman RG, Carlin JB, et al. Subjective scoring of cough in children: parent-completed vs child-completed diary cards vs an objective method. Eur Respir J. 1998;11(2):462-6. [pmid: 9551755].
41 Chang AB, Newman RG, Phelan PD, et al. A new use for an old Holter monitor: an ambulatory cough meter. Eur Respir J. 1997;10(7):1637-9. [pmid: 9230259].
42 Chang AB, Phelan PD, Robertson CF, et al. Relation between measurements of cough severity. Arch Dis Child. 2003;88(1):57-60. [pmid: 12495964].
43 Chernecky C, Sarna L, Waller JL, et al. Assessing coughing and wheezing in lung cancer: a pilot study. Oncol Nurs Forum. 2004;31(6):1095-101. [pmid: 15547632].
44 Corrigan DL, Paton JY. Pilot study of objective cough monitoring in infants. Pediatr Pulmonol. 2003;35(5):350-7. [pmid: 12687591].
45 Coyle MA, Keenan DB, Henderson LS, et al. Evaluation of an ambulatory system for the quantification of cough frequency in patients with chronic obstructive pulmonary disease. Cough. 2005;1:3. [pmid: 16270923].
46 Crawford B, Monz B, Hohlfeld J, et al. Development and validation of a cough and sputum assessment questionnaire. Respir Med. 2008;102(11):1545-55. [pmid: 18662868].
47 Dales RE, White J, Bhumgara C, et al. Parental reporting of childrens' coughing is biased. Eur J Epidemiol. 1997;13(5):541-5. [pmid: 9258566].
48 De Vito Dabbs A, Hoffman LA, Dauber JH, et al. Evaluating the reliability and validity of the Questionnaire for Lung Transplant Patients. Prog Transplant. 2002;12(3):191-8. quiz 9-200. [pmid: 12371045].
49 Decalmer SC, Webster D, Kelsall AA, et al. Chronic cough: how do cough reflex sensitivity and subjective assessments correlate with objective cough counts during ambulatory monitoring?. Thorax. 2007;62(4):329-34. [pmid: 17101736].
50 Dicpinigaitis PV, Tso R, Banauch G. Prevalence of depressive symptoms among patients with chronic cough. Chest. 2006;130(6):1839-43. [pmid: 17167006].
51 Doherty MJ, Mister R, Pearson MG, et al. Capsaicin induced cough in cryptogenic fibrosing alveolitis. Thorax. 2000;55(12):1028-32. [pmid: 11083888].
52 Doherty MJ, Mister R, Pearson MG, et al. Capsaicin responsiveness and cough in asthma and chronic obstructive pulmonary disease. Thorax. 2000;55(8):643-9. [pmid: 10899239].
53 Falconer A, Oldman C, Helms P. Poor agreement between reported and recorded nocturnal cough in asthma. Pediatr Pulmonol. 1993;15(4):209-11. [pmid: 8469572].
54 Faniran AO, Peat JK, Woolcock AJ. Measuring persistent cough in children in epidemiological studies: development of a questionnaire and assessment of prevalence in two countries. Chest. 1999;115(2):434-9. [pmid: 10027444].
55 Faruqi S, Thompson R, Wright C, et al. Quantifying chronic cough: objective versus subjective measurements. Respirology. 2011;16(2):314-20. [pmid: 21054670].
56 Field SK, Conley DP, Thawer AM, et al. Effect of the management of patients with chronic cough by pulmonologists and certified respiratory educators on quality of life: a randomized trial. Chest. 2009;136(4):1021-8. [pmid: 19349387].
57 Fisman EZ, Shapira I, Motro M, et al. The combined cough frequency/severity scoring: a new approach to cough evaluation in clinical settings. J Med. 2001;32(3-4):181-7. [pmid: 11563816].
58 Fletcher KE, French CT, Irwin RS, et al. A prospective global measure, the Punum Ladder, provides more valid assessments of quality of life than a retrospective transition measure. J Clin Epidemiol. 2010;63(10):1123-31. [pmid: 20303709].
59 Freestone C, Eccles R. Assessment of the antitussive efficacy of codeine in cough associated with common cold. J Pharm Pharmacol. 1997;49(10):1045-9. [pmid: 9364418].
60 French CT, Irwin RS, Fletcher KE, et al. Evaluation of a cough-specific quality-of-life questionnaire. Chest. 2002;121(4):1123-31. [pmid: 11948042].
61 Fuller P, Picciotto A, Davies M, et al. Cough and sleep in inner-city children. Eur Respir J. 1998;12(2):426-31. [pmid: 9727796].
62 Hamutcu R, Francis J, Karakoc F, et al. Objective monitoring of cough in children with cystic fibrosis. Pediatr Pulmonol. 2002;34(5):331-5. [pmid: 12357476].
63 Hartnick CJ, Zurakowski D, Haver K. Validation of a pediatric cough questionnaire. Ear Nose Throat J. 2009;88(11):1213-7. [pmid: 19924664].
64 Hoskyns EW, Thomson A, Decker E, et al. Effect of controlled release salbutamol on nocturnal cough in asthma. Arch Dis Child. 1991;66(10):1209-12. [pmid: 1953004].
65 Hsu JY, Stone RA, Logan-Sinclair RB, et al. Coughing frequency in patients with persistent cough: assessment using a 24 hour ambulatory recorder. Eur Respir J. 1994;7(7):1246-53. [pmid: 7925902].
66 Huisman AN, Wu MZ, Uil SM, et al. Reliability and validity of a Dutch version of the Leicester Cough Questionnaire. Cough. 2007;3:3. [pmid: 17313670].
67 Irwin RS, Zawacki JK, Wilson MM, et al. Chronic cough due to gastroesophageal reflux disease: failure to resolve despite total/near-total elimination of esophageal acid. Chest. 2002;121(4):1132-40. [pmid: 11948043].
68 Jones RM, Hilldrup S, Hope-Gill BD, et al. Mechanical induction of cough in Idiopathic Pulmonary Fibrosis. Cough. 2011;7:2. [pmid: 21477349].
69 Kalpaklioglu AF, Kara T, Kurtipek E, et al. Evaluation and impact of chronic cough: comparison of specific vs generic quality-of-life questionnaires. Ann Allergy Asthma Immunol. 2005;94(5):581-5. [pmid: 15945562].
70 Kelsall A, Decalmer S, McGuinness K, et al. Sex differences and predictors of objective cough frequency in chronic cough. Thorax. 2009;64(5):393-8. [pmid: 19131447].
71 Kelsall A, Decalmer S, Webster D, et al. How to quantify coughing: correlations with quality of life in chronic cough. Eur Respir J. 2008;32(1):175-9. [pmid: 18287128].
72 Kelsall A, Houghton LA, Jones H, et al. A novel approach to studying the relationship between subjective and objective measures of cough. Chest. 2011;139(3):569-75. [pmid: 20864619].
73 Key AL, Holt K, Hamilton A, et al. Objective cough frequency in Idiopathic Pulmonary Fibrosis. Cough. 2010;6:4. [pmid: 20565979].
74 Krahnke J, Gentile D, Angelini B, et al. Comparison of objective and subjective measurements of cough frequency in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2004;93(3):259-64. [pmid: 15478386].
75 Krajnik M, Damps-Konstanska I, Gorska L, et al. A portable automatic cough analyser in the ambulatory assessment of cough. Biomed Eng Online. 2010;9:17. [pmid: 20226089].
76 Ma W, Yu L, Wang Y, et al. Changes in health-related quality of life and clinical implications in Chinese patients with chronic cough. Cough. 2009;5:7. [pmid: 19781068].
77 Marsden PA, Smith JA, Kelsall AA, et al. A comparison of objective and subjective measures of cough in asthma. J Allergy Clin Immunol. 2008;122(5):903-7. [pmid: 18842290].
78 Matos S, Birring SS, Pavord ID, et al. An automated system for 24-h monitoring of cough frequency: the Leicester Cough Monitor. IEEE Trans Biomed Eng. 2007;54(8):1472-9. [pmid: 17694868].
79 Monz BU, Sachs P, McDonald J, et al. Responsiveness of the cough and sputum assessment questionnaire in exacerbations of COPD and chronic bronchitis. Respir Med. 2010;104(4):534-41. [pmid: 19917525].
80 Morice AH, Menon MS, Mulrennan SA, et al. Opiate therapy in chronic cough. Am J Respir Crit Care Med. 2007;175(4):312-5. [pmid: 17122382].
81 Murray MP, Turnbull K, MacQuarrie S, et al. Validation of the Leicester Cough Questionnaire in non-cystic fibrosis bronchiectasis. Eur Respir J. 2009;34(1):125-31. [pmid: 19196812].
82 Mwachari C, Nduba V, Nguti R, et al. Validation of a new clinical scoring system for acute bronchitis. Int J Tuberc Lung Dis. 2007;11(11):1253-9. [pmid: 17958990].
83 Nandha D, Goodyer L, Woodruffe-Peacock C. Diary cards and the assessment of cough symptoms in community pharmacies. Pharm World Sci. 2000;22(1):17-20. [pmid: 10815295].
84 Newcombe PA, Sheffield JK, Chang AB. Minimally important change in a Parent-Proxy Quality-of-Life questionnaire for pediatric chronic cough. Chest. 2011;139(3):576-80. [pmid: 20947650].
85 Newcombe PA, Sheffield JK, Juniper EF, et al. Development of a parent-proxy quality-of-life chronic cough-specific questionnaire: clinical impact vs psychometric evaluations. Chest. 2008;133(2):386-95. [pmid: 18252913].
86 Newcombe PA, Sheffield JK, Juniper EF, et al. Validation of a parent-proxy quality of life questionnaire for paediatric chronic cough (PC-QOL). Thorax. 2010;65(9):819-23. [pmid: 20805179].
87 Nieto L, de Diego A, Perpina M, et al. Cough reflex testing with inhaled capsaicin in the study of chronic cough. Respir Med. 2003;97(4):393-400. [pmid: 12693800].
88 Novitsky YW, Zawacki JK, Irwin RS, et al. Chronic cough due to gastroesophageal reflux disease: efficacy of antireflux surgery. Surg Endosc. 2002;16(4):567-71. [pmid: 11972189].
89 O'Connell F, Thomas VE, Pride NB, et al. Capsaicin cough sensitivity decreases with successful treatment of chronic cough. Am J Respir Crit Care Med. 1994;150(2):374-80. [pmid: 8049818].
90 Paul IM, Wai K, Jewell SJ, et al. Evaluation of a new self-contained, ambulatory, objective cough monitor. Cough. 2006;2:7. [pmid: 17005042].
91 Polley L, Yaman N, Heaney L, et al. Impact of cough across different chronic respiratory diseases: comparison of two cough-specific health-related quality of life questionnaires. Chest. 2008;134(2):295-302. [pmid: 18071022].
92 Raj AA, Pavord DI, Birring SS. Clinical cough IV: what is the minimal important difference for the Leicester Cough Questionnaire?. Handb Exp Pharmacol. 2009;(187):311-20. [pmid: 18825348].
93 Ribeiro M, Pereira CA, Nery LE, et al. High-dose inhaled beclomethasone treatment in patients with chronic cough: a randomized placebo-controlled study. Ann Allergy Asthma Immunol. 2007;99(1):61-8. [pmid: 17650832].
94 Shaheen NJ, Crockett SD, Bright SD, et al. Randomised clinical trial: high-dose acid suppression for chronic cough - a double-blind, placebo-controlled study. Aliment Pharmacol Ther. 2011;33(2):225-34. [pmid: 21083673].
95 Smith J, Owen E, Earis J, et al. Cough in COPD: correlation of objective monitoring with cough challenge and subjective assessments. Chest. 2006;130(2):379-85. [pmid: 16899835].
96 Smith J, Owen E, Earis J, et al. Effect of codeine on objective measurement of cough in chronic obstructive pulmonary disease. J Allergy Clin Immunol. 2006;117(4):831-5. [pmid: 16630941].
97 Smith JA, Owen EC, Jones AM, et al. Objective measurement of cough during pulmonary exacerbations in adults with cystic fibrosis. Thorax. 2006;61(5):425-9. [pmid: 16449266].
98 Smith JA, Earis JE, Woodcock AA. Establishing a gold standard for manual cough counting: video versus digital audio recordings. Cough. 2006;2:6. [pmid: 16887019].
99 Vernon M, Kline Leidy N, Nacson A, et al. Measuring cough severity: development and pilot testing of a new seven-item cough severity patient-reported outcome measure. Ther Adv Respir Dis. 2010;4(4):199-208. [pmid: 20519373].
100 Woodcock A, McLeod RL, Sadeh J, et al. The efficacy of a NOP1 agonist (SCH486757) in subacute cough. Lung. Suppl 1. 2010;188:S47-52. [pmid: 19937046].
101 Zihlif N, Paraskakis E, Lex C, et al. Correlation between cough frequency and airway inflammation in children with primary ciliary dyskinesia. Pediatr Pulmonol. 2005;39(6):551-7. [pmid: 15806596].
102 Thomas JS, Lyons HA, Shepherd DA. D.A.T.A.—an advanced automated electronic cough counting system for the evaluation of antitussive agents. Curr Ther Res Clin Exp. 1978;23(1):66-77.
103 Woolf CR, Rosenberg A. Objective assessment of cough suppressants under clinical conditions using a tape recorder system. Thorax. 1964;19:125-30. [pmid: 14128569].
104 Chang AB, Robertson CF, Van Asperen PP, et al. A multi-centre study on chronic cough in children: burden and etiologies based on a standardized management pathway. Chest. 2012. [pmid: 22459773].
105 Leconte S, Liistro G, Lebecque P, et al. The objective assessment of cough frequency: accuracy of the LR102 device. Cough. 2011;7(1):11. [pmid: 22132691].
106 Berkhof FF, Boom LN, ten Hertog NE, et al. The validity and precision of the leicester cough questionnaire in COPD patients with chronic cough. Health and Quality of Life Outcomes. 2012;10.
107 Singapuri A, McKenna S, Brightling CE. The utility of the mannitol challenge in the assessment of chronic cough: a pilot study. Cough. 2008;4:10. [pmid: 19017380].
108 Aliprandi P, Castelli C, Bernorio S, et al. Levocloperastine in the treatment of chronic nonproductive cough: comparative efficacy versus standard antitussive agents. Drugs Exp Clin Res. 2004;30(4):133-41. [pmid: 15553659].
109 Aversa C, Cazzola M, Clini V, et al. Clinical trial of the efficacy and safety of moguisteine in patients with cough associated with chronic respiratory diseases. Drugs Exp Clin Res. 1993;19(6):273-9. [pmid: 8013271].
110 Cass LJ, Frederik WS. Evaluation of a new antitussive agent. N Engl J Med. 1953;249(4):132-6. [pmid: 13063699].
111 Cass LJ, Frederik WS, Andosca JB. Quantitative comparison of dextromethorphan hydrobromide and codeine. Am J Med Sci. 1954;227(3):291-6. [pmid: 13138597].
112 Cass LJ, Frederik WS. Quantitative comparison of cough-suppressing effects of romilar and other antitussives. J Lab Clin Med. 1956;48(6):879-85. [pmid: 13376983].
113 Chaudhuri R, McMahon AD, Thomson LJ, et al. Effect of inhaled corticosteroids on symptom severity and sputum mediator levels in chronic persistent cough. J Allergy Clin Immunol. 2004;113(6):1063-70. [pmid: 15208586].
114 Clarke SW, Lopez-Vidriero MT, Pavia D, et al. The effect of sodium 2-mercapto-ethane sulphonate and hypertonic saline aerosols on bronchial clearance in chronic bronchitis. Br J Clin Pharmacol. 1979;7(1):39-44. [pmid: 104724].
115 Del Donno M, Aversa C, Corsico R, et al. Efficacy and safety of moguisteine in comparison with dextromethorphan in patients with persistent cough. Drug Investigation. 1994;7(2):93-100.
116 Dierckx P, Leblanc G, Decoster A, et al. Double-blind study of glaucine in chronic cough. Int J Clin Pharmacol Ther Toxicol. 1981;19(9):396-9. [pmid: 7028646].
117 Diwan J, Dhand R, Jindal SK, et al. A comparative randomized double-blind clinical trial of isoaminile citrate and chlophedianol hydrochloride as antitussive agents. Int J Clin Pharmacol Ther Toxicol. 1982;20(8):373-5. [pmid: 6749701].
118 Dueholm M, Nielsen C, Thorshauge H, et al. N-acetylcysteine by metered dose inhaler in the treatment of chronic bronchitis: a multi-centre study. Respir Med. 1992;86(2):89-92. [pmid: 1615189].
119 Gastpar H, Criscuolo D, Dieterich HA. Efficacy and tolerability of glaucine as an antitussive agent. Curr Med Res Opin. 1984;9(1):21-7. [pmid: 6373156].
120 Guyatt GH, Townsend M, Kazim F, et al. A controlled trial of ambroxol in chronic bronchitis. Chest. 1987;92(4):618-20. [pmid: 3308343].
121 Holmes PW, Barter CE, Pierce RJ. Chronic persistent cough: use of ipratropium bromide in undiagnosed cases following upper respiratory tract infection. Respir Med. 1992;86(5):425-9. [pmid: 1462022].
122 Jackson IM, Barnes J, Cooksey P. Efficacy and tolerability of oral acetylcysteine (Fabrol) in chronic bronchitis: a double-blind placebo controlled study. J Int Med Res. 1984;12(3):198-206. [pmid: 6376210].
123 Lilienfield LS, Rose JC, Princiotto JV. Antitussive activity of diphenhydramine in chronic cough. Clin Pharmacol Ther. 1976;19(4):421-5. [pmid: 773581].
124 Luporini G, Barni S, Marchi E, et al. Efficacy and safety of levodropropizine and dihydrocodeine on nonproductive cough in primary and metastatic lung cancer. Eur Respir J. 1998;12(1):97-101. [pmid: 9701421].
125 Matthys H, Bleicher B, Bleicher U. Dextromethorphan and codeine: objective assessment of antitussive activity in patients with chronic cough. J Int Med Res. 1983;11(2):92-100. [pmid: 6852361].
126 Matts SG. A trial of Lotussin and linctus diphenhydramine in patients wth an irritant cough. J Int Med Res. 1977;5(6):470-2. [pmid: 338397].
127 Mukaida K, Hattori N, Kondo K, et al. A pilot study of the multiherb Kampo medicine bakumondoto for cough in patients with chronic obstructive pulmonary disease. Phytomedicine. 2011;18(8-9):625-9. [pmid: 21177084].
128 Parvez L, Vaidya M, Sakhardande A, et al. Evaluation of antitussive agents in man. Pulm Pharmacol. 1996;9(5-6):299-308. [pmid: 9232667].
129 Ramsay J, Wright C, Thompson R, et al. Assessment of antitussive efficacy of dextromethorphan in smoking related cough: objective vs. subjective measures. Br J Clin Pharmacol. 2008;65(5):737-41. [pmid: 18279476].
130 Reid JJ. Double-blind trial of ketotifen in childhood chronic cough and wheeze. Immunol Allergy Pract. 1989;11(4):143-50.
131 Ruhle KH, Criscuolo D, Dieterich HA, et al. Objective evaluation of dextromethorphan and glaucine as antitussive agents. Br J Clin Pharmacol. 1984;17(5):521-4. [pmid: 6375709].
132 Sabot G, Bagnato A, Frigerio G. Controlled evaluation of the antitussive activity of viminol p-hydroxybenzoate. Int J Clin Pharmacol Biopharm. 1977;15(4):181-3. [pmid: 323163].
133 Sevelius H, McCoy JF, Colmore JP. Dose response to codeine in patients with chronic cough. Clin Pharmacol Ther. 1971;12(3):449-55. [pmid: 4936034].
134 Simon SW. A comparative study of two new non-narcotic antitussive drugs. Ohio Med. 1957;53(12):1426-7. [pmid: 13493953].
135 Simon SW. Symptomatic treatment of asthmatic bronchitis. J Am Geriatr Soc. 1960;8:107-11. [pmid: 14446944].
136 Tanaka S, Hirata K, Kurihara N, et al. Effect of loratadine, an H1 antihistamine, on induced cough in non-asthmatic patients with chronic cough. Thorax. 1996;51(8):810-4. [pmid: 8795669].
137 Vakil BJ, Mehta AJ, Prajapat KD. Trial of pipazethate as an antitussive. Clin Pharmacol Ther. 1966;7(4):515-9. [pmid: 5328471].
138 van Asperen PP, McKay KO, Mellis CM, et al. A multicentre randomized placebo-controlled double-blind study on the efficacy of Ketotifen in infants with chronic cough or wheeze. J Paediatr Child Health. 1992;28(6):442-6. [pmid: 1466940].
139 van Hengstum M, Festen J, Beurskens C, et al. The effect of positive expiratory pressure versus forced expiration technique on tracheobronchial clearance in chronic bronchitics. Scand J Gastroenterol Suppl. 1988;143:114-8. [pmid: 3291088].
140 Vertigan AE, Theodoros DG, Gibson PG, et al. Efficacy of speech pathology management for chronic cough: a randomised placebo controlled trial of treatment efficacy. Thorax. 2006;61(12):1065-9. [pmid: 16844725].
141 Wei W, Yu L, Wang Y, et al. Efficacy and safety of modified sequential three-step empirical therapy for chronic cough. Respirology. 2010;15(5):830-6. [pmid: 20546197].
142 Wojcicki J, Samochowiec L, Szwed G, et al. The use of Duopect as expectorant–antitussive agent. Arch Immunol Ther Exp (Warsz). 1975;23(1):135-42. [pmid: 1090275].
143 Yousaf N, Monteiro W, Parker D, et al. Long-term low-dose erythromycin in patients with unexplained chronic cough: a double-blind placebo controlled trial. Thorax. 2010;65(12):1107-10. [pmid: 20965928].
144 Marchant J, Masters IB, Champion A, et al. Randomised controlled trial of amoxycillin clavulanate in children with chronic wet cough. Thorax. 2012. [pmid: 22628120].
145 Kuehn BM. Withdrawal of infant cold medicines decreases ED visits by half, CDC finds. JAMA. 2010;304(24):2686. [pmid: 21177501].
146 Bolser DC. Cough suppressant and pharmacologic protussive therapy: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):238S-49S. [pmid: 16428717].
147 Leconte S, Ferrant D, Dory V, et al. Validated methods of cough assessment: a systematic review of the literature. Respiration. 2011;81(2):161-74. [pmid: 21079381].
148 McCool FD, Rosen MJ. Nonpharmacologic airway clearance therapies: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):250S-9S. [pmid: 16428718].
149 American Academy of Pediatrics Committee on Drugs. Use of codeine- and dextromethorphan-containing cough remedies in children. Pediatrics. 1997;99(6):918-20. [pmid: 9190557].
150 U.S. Food and Drug Administration. Public Health Advisory: FDA Recommends that Over-the-Counter (OTC) Cough and Cold Products not be used for Infants and Children under 2 Years of Age. Date of release 1/2008. www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/DrugSafetyInformationforHeathcareProfessionals/PublicHealthAdvisories/ucm051137.htm.
151 Chang AB. Therapy for cough: where does it fall short?. Expert Rev Respir Med. 2011;5(4):503-13. [pmid: 21859270].
152 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.