# Introduction

## Background

### Chronic Cough

In the United States, cough is the most common complaint for which patients seek medical attention and is the second most common reason for a general medical examination, accounting for over 26 million office visits annually.1 Cough often results from an acute, self-limited, viral upper respiratory tract infection; however, there are multiple causes of cough beyond this, including both respiratory tract and nonrespiratory tract-related etiologies. Cough that lasts more than 4 weeks in children younger than 14 years of age or more than 8 weeks in adolescents and adults 14 years of age and older is considered to be chronic by the American College of Chest Physicians (ACCP).2,3 Such chronic cough is responsible for up to 38 percent of pulmonary outpatient visits.4,5 The purpose of this review is to evaluate the effectiveness of instruments to evaluate cough and the comparative effectiveness of treatments for the symptom of cough in patients with either unexplained or refractory chronic cough. Recent studies from the UK, United States, and Japan evaluating patients with chronic cough have estimated that up to 46 percent of patients have idiopathic cough despite a thorough diagnostic investigation.6

Although cough is a troublesome symptom that causes discomfort to patients, it serves a potentially beneficial purpose by clearing the airways of excessive mucus, irritants, or abnormal substances such as edema fluid or pus. But while cough may serve a useful function, it can also lead to a variety of problems, including exhaustion (57%), feeling self-conscious (55%), insomnia (45%), changes in lifestyle (45%), musculoskeletal pain (45%), hoarseness (43%), excessive perspiration (42%), and urinary incontinence (39%).7 These problems are more likely to be prominent in the setting of chronic versus acute cough.

This review focuses on chronic cough because of the significant adverse effects that chronic cough has been shown to have on the quality of patients' lives; if the cause of chronic cough can be identified and properly treated, these adverse effects can be markedly improved.8

### Patient Population

Across all ages, there are many causes of chronic cough, of which more than one may affect any particular patient. The three most common causes of chronic cough in adult nonsmokers who seek medical attention for their cough are upper airway cough syndrome (UACS, formerly known as postnasal drip syndrome), asthma, and gastroesophageal reflux disease (GERD).4,5,9-11 Several prospective studies4-6,10-12 suggest that chronic cough is due to multiple causes 18 to 62 percent of the time. Even in patients for whom the underlying cause of cough has been identified and treated, the symptom of cough may persist and cause continued distress.

In patients with no identifiable cause of cough (unexplained or idiopathic) or no response to specific treatment (unresponsive, refractory, or intractable), chronic cough poses a particularly challenging problem. The differential diagnosis for chronic cough has a different list of etiologies compared with acute cough. Treatment for chronic cough contrasts with acute cough in that acute cough treatment may focus on curing the underlying etiology (e.g., bacterial bronchitis or pneumonia) or suppressing symptoms for the short period of time needed for the etiology to resolve spontaneously (e.g., viral etiologies). Cough becomes chronic if it persists, often due to an underlying etiology that is difficult to diagnose or treat. Therefore, treatments for cough may have differential effectiveness depending on whether the cough is acute versus chronic. Side effects of medication may also become more salient in the setting of chronic cough given that treatment duration is longer, allowing more opportunity for side effects to occur. Chronic cough also differs from acute cough in that quality of life may be affected more severely and in different ways than with acute cough.

For adult patients in whom a specific cause of chronic cough is not easily identified, ACCP 2006 guidelines recommend an empiric approach to diagnosis and treatment.13 This approach begins with a trial of an antihistamine (first-generation) and decongestant (for presumed UACS), followed by an assessment for cough-variant asthma by bronchoprovocation challenge (BPC), followed by a trial of asthma treatment or, if BPC is not available, an empiric trial of antiasthma therapy. If the BPC is negative or an empiric trial of antiasthma treatment is ineffective, then an assessment for nonasthmatic eosinophilic bronchitis (NAEB) is recommended, by induced sputum test for eosinophils. If this test is positive, or if it cannot be performed, then a trial of inhaled corticosteroids is recommended. Finally, if the induced sputum for eosinophils is negative or a trial of corticosteroids is negative, then empiric treatment for GERD is recommended.

Assessment and management of chronic cough in children results in additional uncertainties and concerns. Limitations and possible harms in extrapolating evidence from adults to children are well documented.2,14,15 However, the lack of clinical studies specific to children also limits the available evidence and therefore possible evidence-based options for treating children.14 Within cough specifically, there are both similarities but also clear physiological differences between children and adults and the underlying etiologies. Responses to certain medications have been shown to vary in terms of both their effectiveness and morbidity between adults and children.16-19 Children are therefore an important and distinct population of interest for the management of unexplained or refractory chronic cough.

Patients with a chronic cough in whom an underlying etiology is not defined despite a thorough diagnostic workup are considered to have unexplained chronic cough. Patients in whom an underlying etiology has been identified, but in whom treatment fails to resolve the chronic cough, are considered to have refractory cough. How best to manage and treat patients with refractory cough and patients with unexplained chronic cough is uncertain and is the target of this systematic review.

### Measuring Cough

Accurate, precise measurement of the frequency, severity, quality, and health problems caused by cough, therefore, is important if researchers and clinicians are to better understand the impact of chronic cough, make treatment decisions, and assess efficacy of treatments. Treatment of chronic cough is most successful when therapy can be directed at the underlying etiology; a systematic review has been performed producing a consensus guideline and algorithm to assist with this important process.20 Therapies for the cough symptom (i.e., not specific to the underlying etiology), however, are often used when an etiology is not found or when cough persists despite therapies aimed at underlying etiologies. The purpose of this review is to evaluate the effectiveness of instruments to evaluate cough and the comparative effectiveness of treatments for the symptom of cough for patients with either unexplained or refractory chronic cough.

Measurement methods to formally evaluate cough severity/QOL have had limited acceptance within the broader clinical community. A recent review of treatments for respiratory diseases with cough found that cough was seldom a primary outcome and was most frequently measured using unvalidated scales or as part of an overall symptom score.21 If accurate and reproducible measurement methods can be identified, this may lead to more widespread use of more clinically relevant outcomes in research studies. Such measurement methods could also be useful to practicing clinicians when evaluating the efficacy of chosen treatments or assessing the severity/QOL of a patient's chronic cough.

### Current Treatment Strategies

The diagnosis and management of cough has been the subject of several guideline efforts, two aimed at assessment of cough in adults,13,22 and one focused on children.23 Guidelines from the ACCP, last updated in 2006, are the most comprehensive resource and will be the subject of a future update.13 According to these guidelines, initial clinical evaluation is aimed at determining the cause or underlying etiology of cough based on history, physical examination, and—if the cough is chronic—chest x-ray. Several measurement methods exist to evaluate cough severity, including health-related quality-of-life (HRQOL) instruments, visual analog scales, cough counts (using real-time wearable computerized equipment), and tussigenic challenge. These methods, however, have had limited acceptance within the broader clinical community, and their current use and subsequent impact on clinical decisionmaking and patient outcomes are small.

Identifying the underlying etiology of chronic cough is the most important step of successful management.13 If, however, no cause can be identified, or if treatment of the underlying etiology fails to resolve the cough, then the cough may be treated symptomatically (Table 1), although the efficacy/effectiveness of some of these nonspecific treatments is unclear. In the majority of cases, symptomatic treatment consists of antitussive therapy to decrease cough frequency and severity. Antitussive treatments vary in mechanism of action. Nonspecific antitussives such as dextromethorphan and codeine appear to act in the brain stem to reduce the cough reflex. Other nonspecific antitussives, such as benzonatate, act to anesthetize respiratory passages and thus reduce the stimulus to cough. Other agents aim to decrease the volume of respiratory tract secretions and thus the stimulus and need to cough. These latter antitussive agents are also used to treat certain common underlying etiologies (e.g., UACS, NAEB) and include antihistamines, corticosteroids, antibiotics, decongestants, and mast cell stabilizers. Nonpharmacological antitussives are few but may include, for example, honey. Recently, speech therapy interventions have been used to treat chronic cough in patients suspected of upper airway hypersensitivity.24

Table 1 Commonly used therapies available in the United States for symptomatic treatment of chronic cough

Broad Category | Medication/Therapy Class | Therapy Name
Nonspecific pharmacological antitussives (cough suppressants) | Anesthetics | Benzonatate
Nonspecific pharmacological antitussives (cough suppressants) | Opiates | Codeine, hydrocodone
Nonspecific pharmacological antitussives (cough suppressants) | Other | Dextromethorphan
Nonpharmacological antitussives | Foods | Honey, tea, lemon, liquor
Nonpharmacological antitussives | Psychological | Cognitive behavioral therapy
Nonpharmacological antitussives | Alternative | Acupuncture, tai chi, yoga, meditation
Nonpharmacological antitussives | Multidimensional | Speech therapy
Protussives | Expectorants | Guaifenesin
Protussives | Mucolytic or mucus modifying | Acetylcysteine, dornase alfa inhaled
Nonpharmacological protussives | Physical | Chest physical therapy

In a limited number of situations where cough provides a useful function (such as in bronchiectasis, pneumonia, or atelectasis), protussive therapy may be used in an attempt to increase cough effectiveness without increasing its frequency. Protussive treatments aim to change the characteristics of mucus in such a way that it can be cleared more effectively by mucociliary action or cough. Such effective clearing can subsequently lessen the severity and frequency of a patient's cough. Protussive pharmacological agents include expectorants, mucolytics, and mucus-modifying agents. Examples of these include guaifenesin, hypertonic saline, and acetylcysteine. In addition, physical maneuvers such as chest physical therapy, flutter valves, or pneumatic jackets may be used, especially in patients with respiratory muscle weakness.

Managing the symptom of chronic cough, regardless of whether the etiology is known, is a challenge to even the most experienced health care provider. Several special considerations apply to children (<14 years of age). Duration of treatment, especially in asthmatic children, is not clearly specified in existing guidelines. The benefits of antihistamines in young children (primarily under 12 years of age) with chronic cough are also not clearly understood. Because of the risk of adverse events, the U.S. Food and Drug Administration (FDA) recommends that cough and cold medicines not be used for children under 6 years of age, and the industry has voluntarily withdrawn these medicines for children under 2 years of age. In adults and adolescents (≥14 years of age), management of chronic cough is also challenging, and the appropriate role of the most commonly used antitussive and protussive treatments remains unclear. A review that covers older trials of these commonly used agents, as well as recent trials using newer agents and methodologies, may add significantly to the evidence base for guiding treatment.

## Scope and Key Questions

### Scope of the Review

This comparative effectiveness review (CER) was funded by the Agency for Healthcare Research and Quality (AHRQ) and is designed to evaluate the effectiveness of measurement tools for assessing cough (KQ 1) and the effectiveness of symptomatic treatments for chronic cough (KQ 2).

For KQ 1, the search focused on evaluative studies that compared qualitative and/or quantitative instruments used to assess cough in patients with cough of any duration. The goal was to assess the usefulness of the instruments by considering their diagnostic accuracy and their ability to impact treatment decisions and patient outcomes.

For KQ 2, the search focused on prospective, comparative assessments of pharmacological and nonpharmacological therapies aimed at treating the symptom of cough in patients with chronic cough. Articles were not included if the therapy was directed at an underlying etiology rather than the symptom of cough, if cough resulted from invasive respiratory tract instrumentation, or if the intervention was not available in the United States. A number of patient-oriented outcomes were considered, including cough symptoms and severity, complications related to coughing, functional status, health-related quality of life, and adverse effects of therapy. In addition, studies examining health care utilization and costs were included.

### Key Questions

With input from our Key Informants, we constructed Key Questions (KQs) using the general approach of specifying the population of interest, the interventions, comparators, outcomes, timing of outcomes, and settings (PICOTS; see the section on “Inclusion and Exclusion Criteria” in the Methods chapter for details). The KQs considered in this review were:

- KQ 1: In adults and adolescents (≥ 14 years of age) and children (<14 years of age), what is the comparative diagnostic accuracy, therapeutic efficacy, and patient outcome efficacy of instruments used to assess cough?
- KQ 2: In adults and adolescents (≥ 14 years of age) and children (<14 years of age), what are the comparative safety and effectiveness of nonspecific (or symptomatic) therapies to treat patients with chronic cough?
  a. In patients with unexplained chronic cough
  b. In patients with refractory cough with a known underlying etiology

### Analytic Framework

Figure 1 depicts the KQs within the context of the PICOTS.

Figure 1 Analytic framework

ACE = angiotensin-converting enzyme; GERD = gastroesophageal reflux disease; HRQOL = health-related quality of life; KQ = Key Question; NPV = negative predictive value; PPV = positive predictive value

This figure depicts the two key questions (KQs) within the context of the PICOTS. For KQ 1, the figure shows that there are several instruments that can be used to evaluate the baseline status of patients with chronic cough, as well as used to measure any potential benefits from treatment. KQ 1 considers the diagnostic accuracy of the instruments (including sensitivity, specificity, positive predictive value, negative predictive value, reliability, responsiveness, feasibility, and validity) as well as the therapeutic efficacy (change in clinical practice, impact on patient and provider decisionmaking) and patient outcome efficacy (acceptability, health-related quality of life, chest pain, depression, and anxiety). For KQ 2, the figure shows how antitussive therapies, protussive therapies, and nonpharmacologic therapies for patients with chronic cough may impact patient and health care utilization outcomes. These outcomes include cough symptoms, severity, and frequency; complications related to coughing; patient functional status; health-related quality of life; and health care utilization and related costs. Further, the figure shows that potential harms of therapies (including sleep disturbance, allergic reactions, drowsiness, headache, chest pain, dizziness, and rash) will be assessed along with potential benefits.

This figure depicts the KQs within the context of the PICOTS described above, In general, this figure shows that this CER compares the diagnostic accuracy, therapeutic efficacy, and patient outcome efficacy of instruments to assess the severity, frequency, and impact of cough on patient-centered outcomes (KQ 1), and then the morbidity, adverse events, and health care utilization for patients with unidentified or refractory chronic cough receiving various treatments. Subgroups considered include children 14 years and younger (including exploration of children under 6 years of age, children under 2 years of age, and infants), and patients with differing underlying cough etiologies. Adverse events considered are sleep disturbance, allergic reaction, drowsiness, headache, chest pain, dizziness, and rash. Patient-centered final outcomes include: cough symptoms, cough severity, cough frequency, complications related to cough, functional status, general and cough-specific health-related quality of life, and health care utilization and costs.