# Peer Reviewers

Crystal Smith-Spangler, M.D.

Instructor (Research) Division of General Medicine Disciplines

Stanford School of Medicine

Stanford, CA

Michael H. Baumann, M.D.

Critical Care and Pulmonology

University of Mississippi Medical Center

Jackson, MS

Jaclyn A. Smith, Ph.D.

Respiratory Research Group

University Hospital of South Manchester

Manchester, England

C. Michael Bowman, M.D., Ph.D.

Pediatric Pulmonologist

Medical University of South Carolina

Charleston, SC