# Technical Expert Panel

Kenneth Altman, M.D., Ph.D.

Associate Professor of Otolaryngology

Mount Sinai School of Medicine

New York, NY

Donald C. Bolser, Ph.D.

Associate Professor, Department of Physiological Sciences

College of Veterinary Medicine

University of Florida

Gainesville, FL

Anne Chang, M.B.B.S., Grad. Cert. Tertiary Edu., M.P.H.T.M., Ph.D.

Professor and Senior Specialist

Royal Children's Hospital

Brisbane, Queensland, Australia

Michael Gould, M.D., M.S.

Senior Research Scientist and Assistant Director for Health Services Research Kaiser Permanente

Pasadena, CA

Richard Irwin, M.D.

Professor, University of Massachusetts Medical School

Editor in Chief, CHEST

Worcester, MA

Kaiser Lim, M.D.

Assistant Professor, Pulmonary and Critical Care Medicine, Allergy and Outpatient Infectious Disease, Pediatric and Adolescent Medicine

Mayo Clinic

Rochester, MN

Lorcan P. A. McGarvey, M.D.

Senior Lecturer in Respiratory Medicine

Queen's University of Belfast

Belfast, Northern Ireland, United Kingdom

Bruce Rubin, M.Engr., M.D., M.B.A.

Chair of Pediatrics Department

Virginia Commonwealth University

Richmond, VA