# Key Informants

Kenneth Altman, M.D., Ph.D.

Associate Professor of Otolaryngology

Mount Sinai School of Medicine

New York, NY

Martha Dewey Bergren, D.N.S., R.N., N.C.S.N.

Director of Research, National Association of School Nurse

Adjunct Assistant Professor, Department of Health Systems Science

University of Illinois at Chicago College of Nursing

Chicago, IL

Donald C. Bolser, Ph.D.

Associate Professor, Department of Physiological Sciences

College of Veterinary Medicine

University of Florida

Gainesville, FL

Anne Chang, M.B.B.S., Grad. Cert. Tertiary Edu., M.P.H.T.M., Ph.D.

Professor and Senior Specialist

Royal Children's Hospital

Brisbane, Queensland, Australia

Richard Irwin, M.D.

Professor, University of Massachusetts Medical School

Editor in Chief, CHEST

Worcester, MA

Kaiser Lim, M.D.

Assistant Professor, Pulmonary and Critical Care Medicine, Allergy and Outpatient Infectious Disease, Pediatric and Adolescent Medicine

Mayo Clinic

Rochester, MN

Lorcan P. A. McGarvey, M.D.

Senior Lecturer in Respiratory Medicine Queen's University of Belfast

Belfast, Northern Ireland, United Kingdom

Sarah Ro, M.D.

Chapel Hill Primary Care

Chapel Hill, NC

Bruce Rubin, M.Engr., M.D., M.B.A.

Chair of Pediatrics Department

Virginia Commonwealth University

Richmond, VA

Lawrence Wu, M.D.

Regional Medical Director

Blue Cross Blue Shield of North Carolina

Lead Medical Director for Employee Health

Associate Consulting Professor

Duke School of Medicine

Durham, NC