# QUADAS-2 Scoring of KQ 1 Studies

Study | Methods of patient selection described | Index test described | Reference standard described | Excluded patients described | Random sample | Index test results independent | Reference standard correct | Appropriate interval between tests | Case-control design avoided | Threshold pre-specified | Reference standard results independent | Reference standard for all patients | Inappropriate exclusions avoided | Same reference standard for all | All patients included in analysis | Selection of patients bias | Index text interpretation bias | Reference standard interpretation bias | Patient flow bias | Included patients do not match review question | Index test does not match review question | Target condition does not match review question | Study Rating
Archer, 1985^1^ | Y | Y | Y | N | U | U | Y | Y | Y | U | U | Y | Y | Y | N | N | N | N | N | N | N | N | High risk of bias
Au, 2005^2^ | Y | Y | N | N | N | U | Y | Y | Y | U | U | N | Y | N | N | N | N | N | Y | N | N | N | High risk of bias
Baiardini, 2005^3^ | N | Y | Y | Y | U | U | U | U | Y | U | U | U | U | U | Y | Y | N | Y | Y | Y | N | Y | High risk of bias
Barnabe, 1995^4^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | U | Y | N | N | Y | N | N | N | Low risk of bias
Barry, 2006^5^ | U | Y | U | U | U | Y | Y | U | Y | U | Y | N | U | Y | Y | Y | Y | Y | Y | N | N | N | Low risk of bias
Berkhof, 2012^6^ | N | Y | Y | Y | U | U | U | Y | Y | U | U | Y | Y | Y | Y | N | Y | Y | N | N | N | Y | Low risk of bias
Birring, 2008^7^ | Y | Y | Y | U | Y | Y | Y | Y | N | U | Y | N | Y | N | Y | U | U | N | Y | N | N | N | Low risk of bias
Birring, 2006^8^ | Y | Y | Y | U | Y | U | Y | U | N | U | U | Y | Y | Y | Y | N | Y | N | Y | N | N | N | Low risk of bias
Birring, 2003^9^ | Y | Y | Y | Y | N | U | Y | Y | Y | U | U | Y | Y | Y | Y | Y | U | U | N | N | N | N | Low risk of bias
Braido, 2006^10^ | Y | Y | Y | U | Y | U | Y | U | N | U | U | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Chang, 2012^11^ | Y | Y | Y | U | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Chang, 2003^12^ | Y | Y | Y | Y | U | U | Y | Y | Y | U | U | Y | Y | Y | N | U | N | N | N | N | N | N | Low risk of bias
Chang, 1998^13^ | Y | Y | Y | U | U | U | U | Y | Y | U | Y | U | Y | Y | N | U | U | N | U | N | N | N | Low risk of bias
Chang, 1997^14^ | N | Y | Y | Y | U | U | Y | Y | N | U | U | Y | Y | Y | N | Y | N | N | N | N | N | N | Low risk of bias
Chernecky, 2004^15^ | Y | Y | U | Y | N | U | U | Y | Y | U | U | N | Y | Y | Y | Y | N | Y | Y | N | N | N | High risk of bias
Corrigan, 2003^16^ | Y | Y | Y | Y | U | Y | Y | Y | N | U | Y | N | Y | Y | N | U | N | N | Y | N | N | N | Low risk of bias
Coyle, 2005^17^ | U | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Crawford, 2008^18^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | N | Y | N | N | N | N | N | N | Low risk of bias
Dales, 1997^19^ | N | Y | Y | N | N | Y | Y | Y | Y | U | Y | Y | U | Y | Y | N | N | N | N | Y | N | N | Low risk of bias
De Vito Dabbs, 2002^20^ | Y | Y | Y | N | Y | Y | Y | Y | Y | U | Y | U | Y | U | U | N | N | N | U | Y | Y | N | Low risk of bias
Decalmer, 2007^21^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Dicpinigaitis, 2006^22^ | N | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | U | Y | N | Y | U | N | N | N | High risk of bias
Doherty, 2000^23^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | Low risk of bias
Doherty, 2000^24^ | Y | Y | Y | Y | N | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | N | N | Y | N | N | N | High risk of bias
Falconer, 1993^25^ | N | Y | Y | N | U | Y | Y | Y | Y | U | Y | Y | U | Y | N | Y | N | N | Y | N | N | N | High risk of bias
Faniran, 1999^26^ | Y | Y | U | U | N | Y | U | U | Y | U | U | U | N | U | N | Y | N | U | U | Y | N | U | High risk of bias
Faruqi, 2011^27^ | Y | Y | U | U | U | Y | U | U | Y | U | U | U | Y | U | Y | N | N | U | N | N | N | U | Low risk of bias
Field, 2009^28^ | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | N | N | N | N | N | N | N | N | Low risk of bias
Fisman, 2001^29^ | Y | Y | N | Y | Y | Y | N | N | Y | U | N | N | Y | N | Y | Y | N | N | N | N | N | N | High risk of bias
Fletcher, 2010^30^ | Y | Y | Y | N | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Freestone, 1997^31^ | Y | Y | N | N | U | Y | N | N | Y | U | N | N | Y | N | N | Y | N | N | Y | N | N | N | Low risk of bias
French, 1998^32^ | Y | Y | Y | N | N | Y | Y | Y | Y | U | Y | Y | Y | Y | N | N | N | N | N | N | N | N | Low risk of bias
French, 2002^33^ | Y | Y | N | N | N | Y | N | N | Y | U | N | N | Y | N | Y | N | N | N | N | N | N | N | Low risk of bias
Fuller, 1998^34^ | Y | Y | N | Y | Y | Y | U | Y | Y | U | Y | Y | Y | Y | N | Y | N | Y | Y | N | N | Y | High risk of bias
Hamutcu, 2002^35^ | Y | Y | Y | Y | N | Y | Y | Y | Y | U | Y | U | Y | U | Y | N | Y | Y | N | N | N | N | Low risk of bias
Hartnick, 2009^36^ | Y | Y | U | Y | N | Y | U | Y | Y | U | N | Y | Y | Y | Y | U | U | Y | N | N | N | N | Low risk of bias
Hoskyns, 1991^37^ | Y | Y | N | Y | N | Y | U | Y | Y | U | U | Y | Y | Y | Y | U | N | U | N | N | N | N | Low risk of bias
Hsu, 1994^38^ | N | Y | N | N | N | Y | U | Y | Y | U | U | U | Y | Y | U | N | N | Y | N | N | N | N | Low risk of bias
Huisman, 2007^39^ | U | Y | Y | U | Y | Y | U | Y | Y | U | Y | Y | Y | Y | U | N | N | N | N | N | N | N | Low risk of bias
Irwin, 2002^40^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | Low risk of bias
Jones, 2011^41^ | U | Y | Y | U | N | Y | Y | Y | Y | U | Y | U | Y | Y | U | N | N | N | N | N | N | N | Low risk of bias
Kalpaklioglu, 2005^42^ | U | Y | Y | U | Y | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Kelsall, 2011^43^ | Y | Y | Y | Y | U | U | Y | Y | Y | U | U | Y | Y | Y | N | Y | N | N | Y | N | N | N | Low risk of bias
Kelsall, 2009^44^ | Y | Y | Y | Y | Y | Y | U | Y | Y | U | Y | Y | Y | Y | N | N | N | N | Y | N | N | Y | Low risk of bias
Kelsall, 2008^45^ | Y | Y | Y | Y | U | U | Y | Y | Y | U | U | Y | Y | Y | N | Y | U | U | U | N | N | N | Low risk of bias
Key, 2010^46^ | N | Y | Y | U | N | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | N | N | N | N | N | N | Low risk of bias
Krahnke, 2004^47^ | U | Y | Y | N | U | Y | Y | Y | Y | U | Y | Y | Y | Y | U | U | N | N | N | N | N | N | Low risk of bias
Krajnik, 2010^48^ | Y | Y | Y | Y | N | Y | Y | Y | Y | U | Y | N | Y | Y | N | N | N | N | N | N | N | N | Low risk of bias
Leconte, 2011^49^ | N | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | Low risk of bias
Ma, 2009^50^ | U | Y | Y | N | Y | U | Y | Y | Y | U | U | Y | Y | Y | U | N | N | Y | U | N | N | N | Low risk of bias
Marsden, 2008^51^ | U | Y | Y | U | N | Y | Y | Y | Y | U | Y | U | Y | Y | U | U | N | U | N | N | N | N | Low risk of bias
Matos, 2007^52^ | U | Y | Y | U | N | Y | Y | Y | Y | U | Y | Y | Y | Y | N | N | N | N | N | N | N | N | Low risk of bias
Monz, 2010^53^ | Y | Y | Y | U | N | Y | Y | Y | Y | U | Y | Y | Y | Y | U | U | N | N | N | N | N | N | Low risk of bias
Morice, 2007^54^ | Y | Y | Y | Y | N | Y | Y | Y | Y | U | Y | Y | U | Y | U | U | N | N | U | N | N | N | Low risk of bias
Murray, 2009^55^ | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | U | Y | N | N | N | Y | N | Y | Low risk of bias
Mwachari, 2007^56^ | Y | Y | U | U | U | Y | U | U | Y | U | U | U | Y | U | Y | Y | N | U | N | N | Y | U | Low risk of bias
Nandha, 2000^57^ | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | Y | Y | N | Y | N | N | N | N | Low risk of bias
Newcombe, 2011^58^ | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | U | Y | N | N | U | N | N | N | Low risk of bias
Newcombe, 2010^59^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | N | N | U | N | N | N | Low risk of bias
Newcombe, 2008^60^ | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | Y | Y | Y | U | Y | N | U | U | N | N | N | Low risk of bias
Nieto, 2003^61^ | Y | Y | U | U | U | Y | U | U | Y | Y | U | U | Y | U | U | Y | N | U | U | N | N | U | Low risk of bias
Novitsky, 2002^62^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
O'Connell 1994^63^ | Y | Y | Y | Y | Y | Y | U | Y | Y | U | Y | Y | Y | Y | Y | N | N | Y | N | N | N | N | Low risk of bias
Paul, 2006^64^ | N | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | U | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Polley, 2008^65^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Raj, 2009^66^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Ribeiro, 2007^67^ | Y | Y | Y | Y | Y | Y | U | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Shaheen, 2011^68^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | U | N | N | N | Y | N | N | Low risk of bias
Singapuri, 2008^69^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Smith, 2006^70^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Smith, 2006^71^ | Y | Y | Y | Y | Y | Y | Y | Y | Y | U | Y | Y | Y | Y | U | N | N | N | U | N | N | Y | Low risk of bias
Smith, 2006^72^ | Y | Y | Y | N | U | Y | Y | Y | Y | U | Y | Y | Y | Y | N | N | N | N | N | N | N | N | Low risk of bias
Smith, 2006^73^ | Y | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | Y | N | N | N | Low risk of bias
Thomas, 1978^74^ | N | Y | Y | Y | U | Y | Y | Y | Y | U | Y | Y | U | Y | U | Y | N | N | N | N | N | N | Low risk of bias
Vernon, 2010^75^ | Y | Y | Y | Y | N | Y | Y | Y | Y | U | Y | Y | Y | Y | Y | N | N | N | N | N | N | N | Low risk of bias
Woodcock, 2010^76^ | Y | Y | Y | N | U | Y | Y | Y | Y | U | U | U | Y | U | Y | Y | N | Y | N | N | N | N | Low risk of bias
Woolf, 1964^77^ | N | N | Y | U | U | U | Y | Y | Y | U | Y | Y | U | Y | U | Y | N | N | N | Y | Y | N | High risk of bias
Zihlif, 2005^78^ | Y | U | Y | N | U | Y | Y | Y | Y | U | Y | U | Y | Y | U | Y | N | N | U | Y | N | N | Low risk of bias

Abbreviations: N = No; Y = Yes; U = Unclear

## References to Appendix E

1 Archer LN, Simpson H. Night cough counts and diary card scores in asthma. Arch Dis Child. 1985;60(5):473-4. [pmid: 4015154].
2 Au DH, Blough DK, Kirchdoerfer L, et al. Development of a quantifiable symptom assessment tool for patients with chronic bronchitis: the Chronic Bronchitis Symptoms Assessment Scale. COPD. 2005;2(2):209-16. [pmid: 17136947].
3 Baiardini I, Braido F, Fassio O, et al. A new tool to assess and monitor the burden of chronic cough on quality of life: Chronic Cough Impact Questionnaire. Allergy. 2005;60(4):482-8. [pmid: 15727580].
4 Barnabe R, Berni F, Clini V, et al. The efficacy and safety of moguisteine in comparison with codeine phosphate in patients with chronic cough. Monaldi Arch Chest Dis. 1995;50(2):93-7. [pmid: 7613554].
5 Barry SJ, Dane AD, Morice AH, et al. The automatic recognition and counting of cough. Cough. 2006;2:8. [pmid: 17007636].
6 Berkhof FF, Boom LN, ten Hertog NE, et al. The validity and precision of the leicester cough questionnaire in COPD patients with chronic cough. Health and Quality of Life Outcomes. 2012;10.
7 Birring SS, Fleming T, Matos S, et al. The Leicester Cough Monitor: preliminary validation of an automated cough detection system in chronic cough. Eur Respir J. 2008;31(5):1013-8. [pmid: 18184683].
8 Birring SS, Matos S, Patel RB, et al. Cough frequency, cough sensitivity and health status in patients with chronic cough. Respir Med. 2006;100(6):1105-9. [pmid: 16266801].
9 Birring SS, Prudon B, Carr AJ, et al. Development of a symptom specific health status measure for patients with chronic cough: Leicester Cough Questionnaire (LCQ). Thorax. 2003;58(4):339-43. [pmid: 12668799].
10 Braido F, Baiardini I, Tarantini F, et al. Chronic cough and QoL in allergic and respiratory diseases measured by a new specific validated tool-CCIQ. J Investig Allergol Clin Immunol. 2006;16(2):110-6. [pmid: 16689184].
11 Chang AB, Robertson CF, Van Asperen PP, et al. A multi-centre study on chronic cough in children: burden and etiologies based on a standardized management pathway. Chest. 2012. [pmid: 22459773].
12 Chang AB, Phelan PD, Robertson CF, et al. Relation between measurements of cough severity. Arch Dis Child. 2003;88(1):57-60. [pmid: 12495964].
13 Chang AB, Newman RG, Carlin JB, et al. Subjective scoring of cough in children: parent-completed vs child-completed diary cards vs an objective method. Eur Respir J. 1998;11(2):462-6. [pmid: 9551755].
14 Chang AB, Newman RG, Phelan PD, et al. A new use for an old Holter monitor: an ambulatory cough meter. Eur Respir J. 1997;10(7):1637-9. [pmid: 9230259].
15 Chernecky C, Sarna L, Waller JL, et al. Assessing coughing and wheezing in lung cancer: a pilot study. Oncol Nurs Forum. 2004;31(6):1095-101. [pmid: 15547632].
16 Corrigan DL, Paton JY. Pilot study of objective cough monitoring in infants. Pediatr Pulmonol. 2003;35(5):350-7. [pmid: 12687591].
17 Coyle MA, Keenan DB, Henderson LS, et al. Evaluation of an ambulatory system for the quantification of cough frequency in patients with chronic obstructive pulmonary disease. Cough. 2005;1:3. [pmid: 16270923].
18 Crawford B, Monz B, Hohlfeld J, et al. Development and validation of a cough and sputum assessment questionnaire. Respir Med. 2008;102(11):1545-55. [pmid: 18662868].
19 Dales RE, White J, Bhumgara C, et al. Parental reporting of childrens' coughing is biased. Eur J Epidemiol. 1997;13(5):541-5. [pmid: 9258566].
20 De Vito Dabbs A, Hoffman LA, Dauber JH, et al. Evaluating the reliability and validity of the Questionnaire for Lung Transplant Patients. Prog Transplant. 2002;12(3):191-8. quiz 9-200. [pmid: 12371045].
21 Decalmer SC, Webster D, Kelsall AA, et al. Chronic cough: how do cough reflex sensitivity and subjective assessments correlate with objective cough counts during ambulatory monitoring?. Thorax. 2007;62(4):329-34. [pmid: 17101736].
22 Dicpinigaitis PV, Tso R, Banauch G. Prevalence of depressive symptoms among patients with chronic cough. Chest. 2006;130(6):1839-43. [pmid: 17167006].
23 Doherty MJ, Mister R, Pearson MG, et al. Capsaicin induced cough in cryptogenic fibrosing alveolitis. Thorax. 2000;55(12):1028-32. [pmid: 11083888].
24 Doherty MJ, Mister R, Pearson MG, et al. Capsaicin responsiveness and cough in asthma and chronic obstructive pulmonary disease. Thorax. 2000;55(8):643-9. [pmid: 10899239].
25 Falconer A, Oldman C, Helms P. Poor agreement between reported and recorded nocturnal cough in asthma. Pediatr Pulmonol. 1993;15(4):209-11. [pmid: 8469572].
26 Faniran AO, Peat JK, Woolcock AJ. Measuring persistent cough in children in epidemiological studies: development of a questionnaire and assessment of prevalence in two countries. Chest. 1999;115(2):434-9. [pmid: 10027444].
27 Faruqi S, Thompson R, Wright C, et al. Quantifying chronic cough: objective versus subjective measurements. Respirology. 2011;16(2):314-20. [pmid: 21054670].
28 Field SK, Conley DP, Thawer AM, et al. Effect of the management of patients with chronic cough by pulmonologists and certified respiratory educators on quality of life: a randomized trial. Chest. 2009;136(4):1021-8. [pmid: 19349387].
29 Fisman EZ, Shapira I, Motro M, et al. The combined cough frequency/severity scoring: a new approach to cough evaluation in clinical settings. J Med. 2001;32(3-4):181-7. [pmid: 11563816].
30 Fletcher KE, French CT, Irwin RS, et al. A prospective global measure, the Punum Ladder, provides more valid assessments of quality of life than a retrospective transition measure. J Clin Epidemiol. 2010;63(10):1123-31. [pmid: 20303709].
31 Freestone C, Eccles R. Assessment of the antitussive efficacy of codeine in cough associated with common cold. J Pharm Pharmacol. 1997;49(10):1045-9. [pmid: 9364418].
32 French CL, Irwin RS, Curley FJ, et al. Impact of chronic cough on quality of life. Arch Intern Med. 1998;158(15):1657-61. [pmid: 9701100].
33 French CT, Irwin RS, Fletcher KE, et al. Evaluation of a cough-specific quality-of-life questionnaire. Chest. 2002;121(4):1123-31. [pmid: 11948042].
34 Fuller P, Picciotto A, Davies M, et al. Cough and sleep in inner-city children. Eur Respir J. 1998;12(2):426-31. [pmid: 9727796].
35 Hamutcu R, Francis J, Karakoc F, et al. Objective monitoring of cough in children with cystic fibrosis. Pediatr Pulmonol. 2002;34(5):331-5. [pmid: 12357476].
36 Hartnick CJ, Zurakowski D, Haver K. Validation of a pediatric cough questionnaire. Ear Nose Throat J. 2009;88(11):1213-7. [pmid: 19924664].
37 Hoskyns EW, Thomson A, Decker E, et al. Effect of controlled release salbutamol on nocturnal cough in asthma. Arch Dis Child. 1991;66(10):1209-12. [pmid: 1953004].
38 Hsu JY, Stone RA, Logan-Sinclair RB, et al. Coughing frequency in patients with persistent cough: assessment using a 24 hour ambulatory recorder. Eur Respir J. 1994;7(7):1246-53. [pmid: 7925902].
39 Huisman AN, Wu MZ, Uil SM, et al. Reliability and validity of a Dutch version of the Leicester Cough Questionnaire. Cough. 2007;3:3. [pmid: 17313670].
40 Irwin RS, Zawacki JK, Wilson MM, et al. Chronic cough due to gastroesophageal reflux disease: failure to resolve despite total/near-total elimination of esophageal acid. Chest. 2002;121(4):1132-40. [pmid: 11948043].
41 Jones RM, Hilldrup S, Hope-Gill BD, et al. Mechanical induction of cough in Idiopathic Pulmonary Fibrosis. Cough. 2011;7:2. [pmid: 21477349].
42 Kalpaklioglu AF, Kara T, Kurtipek E, et al. Evaluation and impact of chronic cough: comparison of specific vs generic quality-of-life questionnaires. Ann Allergy Asthma Immunol. 2005;94(5):581-5. [pmid: 15945562].
43 Kelsall A, Houghton LA, Jones H, et al. A novel approach to studying the relationship between subjective and objective measures of cough. Chest. 2011;139(3):569-75. [pmid: 20864619].
44 Kelsall A, Decalmer S, McGuinness K, et al. Sex differences and predictors of objective cough frequency in chronic cough. Thorax. 2009;64(5):393-8. [pmid: 19131447].
45 Kelsall A, Decalmer S, Webster D, et al. How to quantify coughing: correlations with quality of life in chronic cough. Eur Respir J. 2008;32(1):175-9. [pmid: 18287128].
46 Key AL, Holt K, Hamilton A, et al. Objective cough frequency in Idiopathic Pulmonary Fibrosis. Cough. 2010;6:4. [pmid: 20565979].
47 Krahnke J, Gentile D, Angelini B, et al. Comparison of objective and subjective measurements of cough frequency in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2004;93(3):259-64. [pmid: 15478386].
48 Krajnik M, Damps-Konstanska I, Gorska L, et al. A portable automatic cough analyser in the ambulatory assessment of cough. Biomed Eng Online. 2010;9:17. [pmid: 20226089].
49 Leconte S, Liistro G, Lebecque P, et al. The objective assessment of cough frequency: accuracy of the LR102 device. Cough. 2011;7(1):11. [pmid: 22132691].
50 Ma W, Yu L, Wang Y, et al. Changes in health-related quality of life and clinical implications in Chinese patients with chronic cough. Cough. 2009;5:7. [pmid: 19781068].
51 Marsden PA, Smith JA, Kelsall AA, et al. A comparison of objective and subjective measures of cough in asthma. J Allergy Clin Immunol. 2008;122(5):903-7. [pmid: 18842290].
52 Matos S, Birring SS, Pavord ID, et al. An automated system for 24-h monitoring of cough frequency: the Leicester Cough Monitor. IEEE Trans Biomed Eng. 2007;54(8):1472-9. [pmid: 17694868].
53 Monz BU, Sachs P, McDonald J, et al. Responsiveness of the cough and sputum assessment questionnaire in exacerbations of COPD and chronic bronchitis. Respir Med. 2010;104(4):534-41. [pmid: 19917525].
54 Morice AH, Menon MS, Mulrennan SA, et al. Opiate therapy in chronic cough. Am J Respir Crit Care Med. 2007;175(4):312-5. [pmid: 17122382].
55 Murray MP, Turnbull K, MacQuarrie S, et al. Validation of the Leicester Cough Questionnaire in non-cystic fibrosis bronchiectasis. Eur Respir J. 2009;34(1):125-31. [pmid: 19196812].
56 Mwachari C, Nduba V, Nguti R, et al. Validation of a new clinical scoring system for acute bronchitis. Int J Tuberc Lung Dis. 2007;11(11):1253-9. [pmid: 17958990].
57 Nandha D, Goodyer L, Woodruffe-Peacock C. Diary cards and the assessment of cough symptoms in community pharmacies. Pharm World Sci. 2000;22(1):17-20. [pmid: 10815295].
58 Newcombe PA, Sheffield JK, Chang AB. Minimally important change in a Parent-Proxy Quality-of-Life questionnaire for pediatric chronic cough. Chest. 2011;139(3):576-80. [pmid: 20947650].
59 Newcombe PA, Sheffield JK, Juniper EF, et al. Validation of a parent-proxy quality of life questionnaire for paediatric chronic cough (PC-QOL). Thorax. 2010;65(9):819-23. [pmid: 20805179].
60 Newcombe PA, Sheffield JK, Juniper EF, et al. Development of a parent-proxy quality-of-life chronic cough-specific questionnaire: clinical impact vs psychometric evaluations. Chest. 2008;133(2):386-95. [pmid: 18252913].
61 Nieto L, de Diego A, Perpina M, et al. Cough reflex testing with inhaled capsaicin in the study of chronic cough. Respir Med. 2003;97(4):393-400. [pmid: 12693800].
62 Novitsky YW, Zawacki JK, Irwin RS, et al. Chronic cough due to gastroesophageal reflux disease: efficacy of antireflux surgery. Surg Endosc. 2002;16(4):567-71. [pmid: 11972189].
63 O'Connell F, Thomas VE, Pride NB, et al. Capsaicin cough sensitivity decreases with successful treatment of chronic cough. Am J Respir Crit Care Med. 1994;150(2):374-80. [pmid: 8049818].
64 Paul IM, Wai K, Jewell SJ, et al. Evaluation of a new self-contained, ambulatory, objective cough monitor. Cough. 2006;2:7. [pmid: 17005042].
65 Polley L, Yaman N, Heaney L, et al. Impact of cough across different chronic respiratory diseases: comparison of two cough-specific health-related quality of life questionnaires. Chest. 2008;134(2):295-302. [pmid: 18071022].
66 Raj AA, Pavord DI, Birring SS. Clinical cough IV:what is the minimal important difference for the Leicester Cough Questionnaire?. Handb Exp Pharmacol. 2009;(187):311-20. [pmid: 18825348].
67 Ribeiro M, Pereira CA, Nery LE, et al. High-dose inhaled beclomethasone treatment in patients with chronic cough: a randomized placebo-controlled study. Ann Allergy Asthma Immunol. 2007;99(1):61-8. [pmid: 17650832].
68 Shaheen NJ, Crockett SD, Bright SD, et al. Randomised clinical trial: high-dose acid suppression for chronic cough—a double-blind, placebo-controlled study. Aliment Pharmacol Ther. 2011;33(2):225-34. [pmid: 21083673].
69 Singapuri A, McKenna S, Brightling CE. The utility of the mannitol challenge in the assessment of chronic cough: a pilot study. Cough. 2008;4:10. [pmid: 19017380].
70 Smith J, Owen E, Earis J, et al. Cough in COPD: correlation of objective monitoring with cough challenge and subjective assessments. Chest. 2006;130(2):379-85. [pmid: 16899835].
71 Smith JA, Owen EC, Jones AM, et al. Objective measurement of cough during pulmonary exacerbations in adults with cystic fibrosis. Thorax. 2006;61(5):425-9. [pmid: 16449266].
72 Smith J, Owen E, Earis J, et al. Effect of codeine on objective measurement of cough in chronic obstructive pulmonary disease. J Allergy Clin Immunol. 2006;117(4):831-5. [pmid: 16630941].
73 Smith JA, Earis JE, Woodcock AA. Establishing a gold standard for manual cough counting: video versus digital audio recordings. Cough. 2006;2:6. [pmid: 16887019].
74 Thomas JS, Lyons HA, Shepherd DA. D.A.T.A.—an advanced automated electronic cough counting system for the evaluation of antitussive agents. Curr Ther Res Clin Exp. 1978;23(1):66-77. PMID:.
75 Vernon M, Kline Leidy N, Nacson A, et al. Measuring cough severity: development and pilot testing of a new seven-item cough severity patient-reported outcome measure. Ther Adv Respir Dis. 2010;4(4):199-208. [pmid: 20519373].
76 Woodcock A, McLeod RL, Sadeh J, et al. The efficacy of a NOP1 agonist (SCH486757) in subacute cough. Lung. Suppl 1. 2010;188:S47-52. [pmid: 19937046].
77 Woolf CR, Rosenberg A. Objective assessment of cough suppressants under clinical conditions using a tape recorder system. Thorax. 1964;19:125-30. [pmid: 14128569].
78 Zihlif N, Paraskakis E, Lex C, et al. Correlation between cough frequency and airway inflammation in children with primary ciliary dyskinesia. Pediatr Pulmonol. 2005;39(6):551-7. [pmid: 15806596].