# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Full text not available

Abramson MJ, Schattner RL, Holton C, et al. Spirometry and regular follow-up do not improve outcomes in children or adolescents with asthma. Respirology. 2012;17:50. [pmid: 22040022].
Agondi R, Kalil J, Giavina-Bianchi P. Gastroesophageal reflux in patients with chronic cough. Journal of Allergy and Clinical Immunology. 2012;129(2):AB9.
Albloushi A, Simpson S, Stick S, et al. Feasibility and safety of mannitol challenge in pre-school children using forced oscilations. Respirology. 2012;17:4.
Boom L, Vaessen D, Uil S, et al. The effects of montelukast in patients with chronic cough and bronchial hyperreactivity. Chest. 2011;140(4).
Cheng CL, Kao YHY, Lin SJ. Safety and cough and cold medicines in children in Taiwan. Pharmacoepidemiology and Drug Safety. 2011;20:S318-319.
Dockry RJ, Sunger K, Marsden P, et al. Investigating patterns in 24 hours of coughing. Thorax. 2011;66:A65.
Kerwin E, Tashkin DP, Matiz-Bueno CE, et al. Clinical efficacy and safety of combined mometasone furoate and formoterol in patients with moderate to very severe chronic obstructive pulmonary disease (COPD). Journal of Allergy and Clinical Immunology. 2012;129(2):AB201.
Khalid S, Dockry R, Holt K, et al. Cough responses to tussive agents in health and disease. Thorax. 2011;66:A64.
Kurasirikul S, Vichyanond P, Piboonpocanun O, et al. Efficacy of gentamicin nasal irrigation in chronic rhinosinusitis in children. Journal of Allergy and Clinical Immunology. 2012;129(2):AB44.
Lake C, Briffa P, Munoz P, et al. Documentation of cough provoked during a mannitol challenge using acoustic respiratory monitoring compared to video surveillance monitoring. Repriology. 2012;17:1.
Lee KK, Matos S, Evans DH, et al. Predictors of 24-H cough frequency in acute cough. Thorax. 2011;66:A64.
Li Y, Wang H. 100 Cases of children cough and gasp treated by fire needling. Chinese Journal of Acupuncture and Moxibustion. 1991;4(2):117-118.
Maesen F, Smeets J, Hoogslag MA. Azipranone (RU 20.201), a new cough suppressant. A clinical trial using objective and subjective parameters. Tijdschrift voor Geneesmiddelenonderzoek. 1983;8(7):1941-1944.
Perrem LM, O'Neill MB. Can questionnaire completion, by parents, obviate the need for outpatient assessments of their children with respiratory diseases?. Irish Journal of Medical Science. 2011;180:S452.
Quittner A, Marciel K, Kimberg C, et al. Content validity of a disease-specific patient-reported outcome for bronchiectasis. Chest. 2011;140(4).
Saini G, McKeever T, Johnson S, et al. Thalidomide as treatment for IPF associated cough. Thorax. 2011;66:A103.
Smith SM, MacAuslan J, Goldhor R, et al. Using acoustic analysis of coughs to identify respiratory infections in the emergency department. Academic Emergency Medicine. 2012;19:S302.
Spector S, Tan R, Lee R. Cough vs wheezing during methacholine challenge. Chest. 2011;140(4).
Usta Guc B, Asilsoy S, Durmaz C. Bronchial hyperactivity in children with chronic cough. Allergy: European Journal of Allergy and Clinical Immunology. 2011;66:199.
Usta Guc B, Asilsoy S, Durmaz C. Bronchial hyperactivity in patients with rhinitis who consulted due to chronic cough. Allergy: European Journal of Allergy and Clinical Immunology. 2011;66:199.
Vertigan A, Gibson P. Development of a brief speech pathology intervention for chronic refractory cough. Pulmonary Pharmacology and Therapeutics. 2011;24(3):e5.
Willis C, Robertson CF, Van Asperen PP, et al. A multi-centre study on chronic cough: burden and etiologies based on a standardized management pathway. Respirology. 2012;17:79. [pmid: 21883679].
Zanasi A, Lanata L, De Danieli G, et al. Cough incidence, impact on sleep, and antitussive treatment in the pediatric population. Chest. 2011;140(4).
Zhang Y. The values of fractional exhaled nitric oxide in the diagnosis and treatment of chronic cough. Respirology. 2011;16:213.

## Non-English language

Adamko DJ, Majaesic CM, Skappak C, et al. A pilot on the treatment of gastroesophageal reflux-related cough in infants. Zhongguo Dang Dai Er Ke Za Zhi. 2012;14(5):321-7. [pmid: 22613099].
Carrasquer A, Targarona EM, Mannello F, et al. Laparoscopic fundoplication results in the treatment of the non-gastrointestinal symptoms of gastroesophageal reflux. Cir Esp. 2012;90(4):238-42. [pmid: 22404897].
Ghaffari J, Saffar M, Salehifar E, et al. Anti-cough effects of tramadol in patients with pertussis. Journal of Mazaridaran University of Medical Sciences. 2011;21(84):106-111.
Ghodrati S, Hormati A, Mousavi NN, et al. Comparison of FEV1 and PEF values in cough variant asthma during methacholine challenge test. Journal of Zanjan University of Medical Sciences and Health Services. 2011;19(77):3.
Ghodrati S, Mousavinasab SN, Pezeshki B, et al. Prevalence of cough variant asthma in patients with chronic cough attending to Vali-e Asr hospital of Zanjan, Iran, 2009. Journal of Zanjan University of Medical Sciences and Health Services. 2011;19(76).
Kardos P, Gebhardt T. Chronic persistent cough (CPH) in the medical practice: Diagnostics and treatment of 329 patients in 2 years. Pneumologie. 1996;50(6):437-441. [pmid: 8766375].
Pacheco A, Faro V, Cobeta I, et al. Chronic cough with limited response to treatment and incidence of gastroesophageal reflux. Archivos de Bronconeumologia. 2012;48(6):197-201. [pmid: 22421522].
Zhang YM, Lin JT. The values of fractional exhaled nitric oxide for the diagnosis and treatment response evaluation of chronic cough. Respirology. 2011;16:219.

## Study population is not human

Chakraborty D, Shah B. Antimicrobial, anti-oxidative and anti-hemolytic activity of Piper betel leaf extracts. International Journal of Pharmacy and Pharmaceutical Sciences. 2011;3(SUPPL. 3):192-199.
Harsanyi K, Tardos L, Feher I, et al. Pharmacologic, clinico-pharmacologic and clinical effects of Libexin. Boll Chim Farm. 1973;112(10):691-9. [pmid: 4782264].
Schneider CR, Everett AW, Geelhoed E, et al. Provision of primary care to patients with chronic cough in the community pharmacy setting. Ann Pharmacother. 2011;45(3):402-8. [pmid: 21325099].

## Not an evaluation study (KQ 1), RCT (KQ1 or KQ2), cohort study (KQ1 or KQ2)

Agrawal M. OTC cold, cough and allergy products: more choice or more confusion?. J Hosp Mark. 1999;13(1):79-86. [pmid: 10623197].
Allan GM, Korownyk C, Kolber M. Do cough suppressants or honey help pediatric cough?. Can Fam Physician. 2011;57(4):435. [pmid: 21490355].
Altman KW, Irwin RS. Cough: a new frontier in otolaryngology. Otolaryngol Head Neck Surg. 2011;144(3):348-52. [pmid: 21493194].
Amdekar YK. Cough and asthma. Indian J Pediatr. Suppl 2. 2001;68:S20-5. [pmid: 11411373].
Anderson-James S, Marchant Julie M, O'Grady KA, et al. Inhaled corticosteroids for sub-acute cough in children. 2010;(12). #008888.
Anonymous. Cough medications in children. Drug Ther Bull. 1999;37(3):19-21. [pmid: 10563059].
Anonymous. Cough. Stud Anc Med. 2009;38:225-82. [pmid: 20481150].
Anonymous. Cough medication evaluation. JAMA. 1966;197(7):581-2. [pmid: 5952817].
Anonymous. Cough suppressants ineffective for children. Journal of Family Practice. 2004;53(10):770-772.
Anonymous. Prolonged cough and chronic cough. Respirology. 2006;11(Suppl 4):S141-S142.
Anonymous. Prolonged and chronic cough. Respirology. 2006;11(Suppl 4):S160-S174.
Anonymous. Evaluation of cough. Respirology. 2006;11(Suppl 4):S143-S148.
Anonymous. Acute cough. Respirology. 2006;11(Suppl 4):S152-S159.
Anonymous. Cough in specific populations (paediatric patients, elderly patients and patients with underlying disease). Respirology. 2006;11(Suppl 4):S175-S186.
Axelsson I. Honey, not dextromethorphan, was better than no treatment for nocturnal cough in children with upper respiratory infections: Commentary. Evidence-Based Medicine. 2008;13(4):106. [pmid: 18667665].
Bailey EJ, Chang AB, Thomas D. In children with prolonged cough, does treatment with antibiotics have a better effect on cough resolution than no treatment? Part A: Evidence-based answer and summary. Paediatrics and Child Health. 2008;13(6):512-513. [pmid: 19436433].
Banner AS. Cough: physiology, evaluation, and treatment. Lung. 1986;164(2):79-92. [pmid: 3084882].
Barraclough K. Diagnosis in general practice: Chronic cough in adults. BMJ. 2009;338(7705):1267.
Belvisi MG, Hele DJ. Cough: Citric acid and nerves. Drug Discovery Today: Disease Models. 2006;3(3):237-241.
Berman BA. Habit cough in adolescent children. Ann Allergy. 1966;24(1):43-6. [pmid: 5902120].
Betti JL, Mebere Yemefa'a SR. An ethnobotanical study of medicinal plants used in the Kalamaloue National Park, Cameroon. Journal of Medicinal Plant Research. 2011;5(8):1447-1458.
Bickerman HA, Rodgers JM. Principles of measurement of cough depressing effect. Eur J Respir Dis Suppl. 1980;110:93-100. [pmid: 7011831].
Birring SS. New concepts in the management of chronic cough. Pulm Pharmacol Ther. 2011;24(3):334-8. [pmid: 21255671].
Birring SS, Passant C, Patel RB, et al. Chronic tonsillar enlargement and cough: preliminary evidence of a novel and treatable cause of chronic cough. Eur Respir J. 2004;23(2):199-201. [pmid: 14979491].
Bjornsdottir I, Einarson TR, Gudmundsson LS, et al. Efficacy of diphenhydramine against cough in humans: a review. Pharm World Sci. 2007;29(6):577-83. [pmid: 17486423].
Bolser DC. Cough suppressant and pharmacologic protussive therapy: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):238S-249S. [pmid: 16428717].
Bolser DC. Pharmacologic management of cough. Otolaryngol Clin North Am. 2010;43(1):147-55. xi. [pmid: 20172264].
Bolser DC. Current and future centrally acting antitussives. Respir Physiol Neurobiol. 2006;152(3):349-55. [pmid: 16517221].
Brignall K, Jayaraman B, Birring SS. Quality of life and psychosocial aspects of cough. Lung. Suppl 1. 2008;186:S55-8. [pmid: 17939003].
Brodlie M, Graham C, McKean MC. Childhood Cough. BMJ. 2012;344:e1177. [pmid: 22395925].
Brunk SF. The evaluation of antitussive agents. J Clin Pharmacol. 1973;13(8):305-8. [pmid: 4490005].
Burdon JG. Chronic cough: diagnosis and treatment. Aust Fam Physician. 1987;16(5):596-602. [pmid: 3606497].
Burford JG, George RB. Respiratory physical therapy in the treatment of chronic bronchitis. Semin Respir Infect. 1988;3(1):55-60. [pmid: 3283882].
Burns MW. Chronic cough. Diagnostic and management options. Aust Fam Physician. 1996;25(2):161-2. 166. 7. [pmid: 8839374].
Bye MR. The child with cough. Emergency and Office Pediatrics. 1996;9(1):14-16.
Catania MA, Cuzzocrea S. Pharmacological and clinical overview of cloperastine in treatment of cough. Ther Clin Risk Manag. 2011;7:83-92. [pmid: 21445282].
Chalmers RK. Cough depressants. J Am Pharm Assoc. 1966;6(10):538-42. [pmid: 5977022].
Chang AB. Pediatric cough: children are not miniature adults. Lung. Suppl 1. 2010;188:S33-40. [pmid: 19672656].
Chang AB, Glomb WB. Guidelines for evaluating chronic cough in pediatrics: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):260S-283S. [pmid: 16428719].
Chang AB, Lasserson TJ, Gaffney J, et al. Gastro-oesophageal reflux treatment for prolonged non-specific cough in children and sults. Cochrane Databse of Systematic Reviews. 2011;(1):CD004823.
Chang AB, Marchant JM, McKean MC, et al. Inhaled cromones for prolonged non-specific cough in children. Cochrane Database of Systematic Reviews. 2004;(1):CD004436. [pmid: 15106252].
Chang AB, McKean MC, Morris PS. Anticholinergics for prolonged non-specific cough in children. Cochrane Database of Systematic Reviews. 2003;(4):CD004358.
Chang AB, Winter D, Acworth JP. Leukotriene receptore antagonist for prolionged non-specific cough in children. Cochrane Database of Systematic Reviews. 2006;(2):CD005602. [pmid: 16625643].
Chung KF. Clinical cough VI: the need for new therapies for cough: disease-specific and symptom-related antitussives. Handb Exp Pharmacol. 2009;(187):343-68. [pmid: 18825350].
Chung KF. Effective antitussives for the cough patient: an unmet need. Pulm Pharmacol Ther. 2007;20(4):438-45. [pmid: 17161637].
Chung KF. Measurement of cough. Respir Physiol Neurobiol. 2006;152(3):329-39. [pmid: 16530025].
Chung KF. Pathophysiology and therapy of chronic cough. Minerva Med. 2005;96(1):29-40. [pmid: 15827540].
Chung KF. Assessment and measurement of cough: the value of new tools. Pulm Pharmacol Ther. 2002;15(3):267-72. [pmid: 12099776].
Chung KF. Currently available cough suppressants for chronic cough. Lung. Suppl 1. 2008;186:S82-7. [pmid: 17909897].
Chung KF. Methods of assessing cough and antitussives in man. Pulm Pharmacol. 1996;9(5-6):373-7. [pmid: 9232680].
Chung KF. Clinical cough VI: The need for new therapies for cough: Disease-specific and symptom-related antitussives. 2009;187:343-368.
Chung KF, Lalloo UG. Diagnosis and management of chronic persistent dry cough. Postgrad Med J. 1996;72(852):594-8. [pmid: 8977940].
Cohlan SQ, Stone SM. The cough and the bedsheet. Pediatrics. 1984;74(1):11-5. [pmid: 6739203].
Cooreman J, Redon S, Perdrizet S. Aetiology of chronic coughing among school-children of the Bordeaux area: Methodology of the survey and the preliminary results. Bulletin of the International Union against Tuberculosis. 1982;57(3-4):262-269.
Cowcher K, Hanks GW. Long-term management of respiratory symptoms in advanced cancer. J Pain Symptom Manage. 1990;5(5):320-30. [pmid: 2079581].
Dawson KP, Thorpe CW, Toop LJ. The spectral analysis of cough sounds in childhood respiratory illness. J Paediatr Child Health. 1991;27(1):4-6. [pmid: 2043389].
De Blasio F, Dicpinigaitis PV, Rubin BK, et al. An observational study on cough in children, epidemiology, impact on wuality of sleep and treatment outcome. Cough. 2012;8(1):1. [pmid: 22269875].
De Blasio F, Virchow JC, Polverino M, et al. Cough management: a practical approach. Cough. 2011;7(1):7. [pmid: 21985340].
de Jongste JC, Shields MD. Cough . 2: Chronic cough in children. Thorax. 2003;58(11):998-1003. [pmid: 14586058].
Dicpinigaitis PV. Currently available antitussives. Pulm Pharmacol Ther. 2009;22(2):148-51. [pmid: 18771744].
Dicpinigaitis PV. Experimentally induced cough. Pulm Pharmacol Ther. 2007;20(4):319-24. [pmid: 17113801].
Dicpinigaitis PV. Inhalation cough challenge. Current Respiratory Medicine Reviews. 2010;6(2):142-147.
Dolansky G, Rieder M. What is the evidence for the safety and efficacy of over-the-counter cough and cold preparations for children younger than six years of age?. Paediatr Child Health. 2008;13(2):125-7. [pmid: 19183719].
Donnelly D, Everard MM, Chang AB. Indoor air modification interventions for prolonged non-specific cough in children. Cochrane Database Syst Rev. 3:CD005075. [pmid: 16856075].
du Mont A. Cough & cold preparation. Community Outlook. 1983:296-9. [pmid: 6557885].
Ebell MH. Inhaled beta agonists for chronic, nonspecific cough in children?. Am Fam Physician. 2006;73(7):1191-2. [pmid: 16625712].
Ebell MH. Diagnosis of chronic cough. J Fam Pract. 1996;43(3):231-2. [pmid: 8797745].
Eddy NB. Codeine and its alternates for pain and cough relief. Ann Intern Med. 1969;71(6):1209-12. [pmid: 5361414].
Fontana GA, Widdicombe J. What is cough and what should be measured?. Pulm Pharmacol Ther. 2007;20(4):307-12. [pmid: 17291801].
Fuller RW, Jackson DM. Physiology and treatment of cough. Thorax. 1990;45(6):425-30. [pmid: 2203180].
Gibson PG, Vertigan AE. Speech pathology for chronic cough: a new approach. Pulm Pharmacol Ther. 2009;22(2):159-62. [pmid: 19061964].
Gilbert G. Single dose of honey effective for cough in kids. Journal of the National Medical Association. 2008;100(4):459.
Ginsberg DL. Paroxetine treatment of opioid-resistant, persistent dry cough. Primary Psychiatry. 2004;11(10):24-25.
Goyal M, Sasmal D, Nagori BP. Review on medicinal plants used by local community of jodhpur district of thar desert. International Journal of Pharmacology. 2011;7(3):333-339.
Gupta A, McKean M, Chang AB. Management of chronic non-specific cough in childhood: an evidence-based review. Arch Dis Child Educ Pract Ed. 2007;92(2):33-9. [pmid: 17430858].
Haq F, Ahmad H, Alam M. Traditional uses of medicinal plants of Nandiar Khuwarr catchment (District Battagram), Pakistan. Journal of Medicinal Plant Research. 2011;5(1):39-48.
Harvey HP. Pharmaceutical benefits: disodium cromoglycate. Med J Aust. 1970;2(1):45. [pmid: 5447849].
Hendeles L. Efficacy and safety of antihistamines and expectorants in nonprescription cough and cold preparations. Pharmacotherapy. 1993;13(2):154-8. [pmid: 8097037].
Ing A. Chronic cough. Respirology. 1997;2(4):309-16. [pmid: 9525303].
Irwin RS. Unexplained cough in the adult. Otolaryngol Clin North Am. 2010;43(1):167-80. xi. xii. [pmid: 20172266].
Irwin RS. Assessing cough severity and efficacy of therapy in clinical research: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):232S-237S. [pmid: 16428716].
Irwin RS, Curley FJ. The treatment of cough. A comprehensive review. Chest. 1991;99(6):1477-84. [pmid: 2036833].
Irwin RS, French CT. Cough and gastroesophageal reflux: identifying cough and assessing the efficacy of cough-modifying agents. Am J Med. Suppl 8A. 2001;111:45S-50S. [pmid: 11749924].
Irwin RS, Madison JM. The diagnosis and treatment of cough. N Engl J Med. 2000;343(23):1715-21. [pmid: 11106722].
Irwin RS, French CT, Fletcher KE. Quality of life in coughers. Pulm Pharmacol Ther. 2002;15(3):283-6. [pmid: 12099779].
Johnstone K, Fong Kwun M, Bowman R, et al. Inhaled corticosteroids for subacute and chronic cough in adults. 2011;(9). CD009305.
Karpa KD, Barnes M, Patel A. Treating kids with cough and cold: Filling the void. Drug Topics. 2008;152(5).
Karthishwaran K, Mirunalini S. Therapeutic potential of Pergularia daemia (Forsk.): The ayurvedic wonder. International Journal of Pharmacology. 2010;6(6):836-843.
Kelly LF. Pediatric cough and cold preparations. Pediatr Rev. 2004;25(4):115-23. [pmid: 15060179].
Kerrebijn KF, Hoogeveen-Schroot HC, van der Wal MC. A prospective study on chronic respiratory disease in children. I. Aim and methods, results of the first year. Scand J Respir Dis. 1973;54(1):3-15. [pmid: 4690405].
Khoshoo V, Edell D, Mohnot S, et al. Associated factors in children with chronic cough. Chest. 2009;136(3):811-5. [pmid: 19567488].
Kopriva F, Szotkowska J, Zapalka M. Bronchial asthma and Chlamydia pneumoniae antibodies in children aged 4-8 years in Olomouc district. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2005;149(2):289-91. [pmid: 16601774].
Koskela HO, Purokivi MK, Romppanen J. Neurotrophins in chronic cough: association with asthma but not with cough severity. Clin Respir J. 2010;4(1):45-50. [pmid: 20298417].
Kripke C. Inhaled beta agonists for chronic, nonspecific cough in children?. American Family Physician. 2006;73(7):1193-1194.
Kwon NH, Oh MJ, Min TH, et al. Causes and clinical features of subacute cough. Chest. 2006;129(5):1142-7. [pmid: 16685003].
Laukka MA, Cameron AJ, Schei AJ. Gastroesophageal reflux and chronic cough: which comes first?. J Clin Gastroenterol. 1994;19(2):100-4. [pmid: 7963352].
Lavigne JV, Davis AT, Fauber R. Behavioral management of psychogenic cough: alternative to the “bedsheet” and other aversive techniques. Pediatrics. 1991;87(4):532-7. [pmid: 2011431].
Lavorini F, Fontana GA, Chellini E, et al. Respiratory expulsive efforts evoked by maximal lung emptying. Chest. 2011;140(3):690-6. [pmid: 21106658].
Lavorini F, Pantaleo T, Geri P, et al. Cough and ventilatory adjustments evoked by aerosolised capsaicin and distilled water (fog) in man. Respir Physiol Neurobiol. 2007;156(3):331-9. [pmid: 17134944].
Lee BJ, Jeung YJ, Lee JY, et al. Increased S-nitrosothiol levels in nonasthmatic eosinophilic bronchitis compared with cough variant asthma. Int Arch Allergy Immunol. 2011;156(1):99-103. [pmid: 21447965].
Lee SY, Cho JY, Shim JJ, et al. Airway inflammation as an assessment of chronic nonproductive cough. Chest. 2001;120(4):1114-20. [pmid: 11591547].
Lee SY, Kim MK, Shin C, et al. Substance P-immunoreactive nerves in endobronchial biopsies in cough-variant asthma and classic asthma. Respiration. 2003;70(1):49-53. [pmid: 12584391].
Lim KG. Nitric oxide measurement in chronic cough. Lung. Suppl 1. 2010;188:S19-22. [pmid: 19809852].
LoBuono C. Antitussive offers convenient twicedaily dosing. Drug Topics. 2004;148(14):16.
Loudon RG, Brown LC. Cough frequency in patients with respiratory disease. Am Rev Respir Dis. 1967;96(6):1137-43. [pmid: 6057616].
Lurie A, Mestiri M, Huchon G, et al. Methods for clinical assessment of expectorants: a critical review. Int J Clin Pharmacol Res. 1992;12(1):47-52. [pmid: 1526698].
Maliwichi-Nyirenda CP, Maliwichi LL, Franco M. Medicinal uses of Berberis holstii Engl. (Berberidaceae) in Malawi, the only African endemic barberry. Journal of Medicinal Plant Research. 2011;5(8):1367-1373.
Maranetra N, Chuaychoo B, Lertakyamanee J, et al. The cost-effectiveness of a questionnaire as a screening test for chronic obstructive pulmonary disease among the Bangkok elderly. J Med Assoc Thai. 2003;86(11):1033-41. [pmid: 14696785].
Marchant JM, Morris P, Gaffney JT, et al. Antibiotics for prolonged moist cough in children. Cochrane Database Syst Rev. 2005;(4):CD004822. [pmid: 16235384].
Marchesani F, Cecarini L, Pela R, et al. Causes of chronic persistent cough in adult patients: the results of a systematic management protocol. Monaldi Arch Chest Dis. 1998;53(5):510-4. [pmid: 9861809].
Marshall S. Over-the-counter advice for coughs. Pharmaceutical Journal. 2007;278(7435):85-88.
Matsumoto H, Niimi A, Takemura M, et al. Features of cough variant asthma and classic asthma during methacholine-induced brochoconstriction: a cross-sectional study. Cough. 2009;5:3. [pmid: 19272144].
McGarvey L, Morice AH. Clinical cough II: Therapeutic treatments and management of chronic cough. 2009;187:277-295.
McGarvey LP, Heaney LG, Lawson JT, et al. Evaluation and outcome of patients with chronic non-productive cough using a comprehensive diagnostic protocol. Thorax. 1998;53(9):738-43. [pmid: 10319055].
McKenzie SA, Bridge PD, Healy MJ. Airway resistance and atopy in preschool children with wheeze and cough. Eur Respir J. 2000;15(5):833-8. [pmid: 10853845].
McKenzie SA, Mylonopoulou M, Bridge PD. Bronchodilator responsiveness and atopy in 5-10-yr-old coughers. Eur Respir J. 2001;18(6):977-81. [pmid: 11829105].
Mello CJ, Irwin RS, Curley FJ. Predictive values of the character, timing, and complications of chronic cough in diagnosing its cause. Arch Intern Med. 1996;156(9):997-1003. [pmid: 8624180].
Milla CE, Hansen LG, Warwick WJ. Different frequencies should be prescribed for different high frequency chest compression machines. Biomed Instrum Technol. 2006;40(4):319-24. [pmid: 16941931].
Molassiotis A, Bryan G, Caress A, et al. Pharmacological and non-pharmacological interventions for cough in adults with respiratory and non-respiratory diseases: a systematic review of the literature. Respir Med. 2010;104(7):934-44. [pmid: 20385478].
Morice AH, Fontana GA, Sovijarvi AR, et al. The diagnosis and management of chronic cough. Eur Respir J. 2004;24(3):481-92. [pmid: 15358710].
Mulholland S, Chang AB. Honey and lozenges for children with non-specific cough. Cochrane Database Syst Rev. 2009;(2):CD007523. [pmid: 19370690].
Murata A, Ohota N, Shibuya A, et al. New non-invasive automatic cough counting program based on 6 types of classified cough sounds. Intern Med. 2006;45(6):391-7. [pmid: 16617191].
Okwu DE, Uchenna NF. Exotic multifaceted medicinal plants of drugs and pharmaceutical industries. African Journal of Biotechnology. 2009;8(25):7271-7282.
Patel SS, Mohamed Saleem TS, Ravi V, et al. Passiflora incarnata Linn: A phytopharmacological review. International Journal of Green Pharmacy. 2009;3(4):277-280.
Pavia D. The role of chest physiotherapy in mucus hypersecretion. Lung. 1990;168(Suppl):614-21. [pmid: 2117171].
Priyashree S, Jha S, Pattanayak S. A review on Cressa cretica Linn.: A halophytic plant. Pharmacognosy Reviews. 2010;4(8):161-166. [pmid: 22228956].
Rafferty P. Antihistamines in the treatment of clinical asthma. J Allergy Clin Immunol. 1990;86(4 Pt 2):647-50. [pmid: 1977784].
Raj AA, Birring SS. Clinical assessment of chronic cough severity. Pulm Pharmacol Ther. 2007;20(4):334-7. [pmid: 17113330].
Ramanuja S, Kelkar P. Habit cough. Ann Allergy Asthma Immunol. 2009;102(2):91-5. quiz 95-7, 115. [pmid: 19230457].
Rolfe MW, Alberts WM. The chronic persistent cough. Compr Ther. 1996;22(10):615-21. [pmid: 8950077].
Sadoul P, Puchelle E, Girard F. Criteria for evaluating mucus functions and their disorders in chronic bronchitis. Ciba Found Symp. 1978;(54):277-95. [pmid: 248016].
Sanda KA, Grema HA, Geidam YA, et al. Pharmacological aspects of Psidium guajava: An Update. International Journal of Pharmacology. 2011;7(3):316-324.
Saric-Kundalic B, Fritz E, Dobes C, et al. Traditional medicine in the pristine village of Prokosko lake on Vranica Mountain, Bosnia and Herzegovina. Scientia Pharmaceutica. 2010;78(2):275-290. [pmid: 21179347].
Sause RB, Mangione RA. Cough and cold treatment with OTC medicines. J Pract Nurs. 1991;41(3):15-25. [pmid: 1716321].
Savo V, Giulia C, Maria GP, et al. Folk phytotherapy of the Amalfi Coast (Campania, Southern Italy). Journal of Ethnopharmacology. 2011;135(2):376-392. [pmid: 21419835].
Sharfstein JM, North M, Serwint JR. Over the counter but no longer under the radar--pediatric cough and cold medications. N Engl J Med. 2007;357(23):2321-4. [pmid: 18057333].
Shaw EB. Over-the-counter cough mixtures. JAMA. 1969;208(8):1493. [pmid: 4388776].
Shields MD, Bush A, Everard ML, et al. Recommendations for the assessment and management of cough in children. Thorax. 2008;63(SUPPL. 3):iii1-iii15. [pmid: 17905822].
Smith J. Monitoring chronic cough: current and future techniques. Expert Rev Respir Med. 2010;4(5):673-83. [pmid: 20923344].
Smith J. Ambulatory methods for recording cough. Pulm Pharmacol Ther. 2007;20(4):313-8. [pmid: 17161969].
Smith J, Woodcock A. New developments in the objective assessment of cough. Lung. Suppl 1. 2008;186:S48-54. [pmid: 18066694].
Smith JA. Assessing efficacy of therapy for cough. Otolaryngol Clin North Am. 2010;43(1):157-66. xi. [pmid: 20172265].
Spector S. Use of mannitol inhalation challenge in assessment of cough. Lung. Suppl 1. 2010;188:S99-103. [pmid: 19756864].
Srivastava R, Ahmed H, Dixit R, et al. Crocus sativus L.: A comprehensive review. Pharmacognosy Reviews. 2010;4(8):200-208. [pmid: 22228962].
Subburaj S, Parvez L, Rajagopalan TG. Methods of recording and analysing cough sounds. Pulm Pharmacol. 1996;9(5-6):269-79. [pmid: 9232663].
Tan RA, Spector SL. Chronic cough. Compr Ther. 1997;23(7):467-71. [pmid: 9262921].
Tomerak AA, McGlashan JJ, Vyas HH, et al. Inhaled corticosteroids for non-specific chronic cough in children. Cochrane Database Syst Rev. 2005;(4):CD004231. [pmid: 16235355].
Tomerak AA, Vyas HH, Lakenpaul M, et al. Inhaled beta2-agonists for treating non-specific chronic cough in children. Cochrane Database Syst Rev. 2005;(3):CD005373. [pmid: 16034971].
Torres M. Nonprescription over-the-counter cough and cold medicines for children. International Pediatrics. 2008;23(4):217-218.
Ummarino D, Vandermeulen L, Roosens B, et al. Gastroesophageal reflux evaluation in adult patients affected by chronic cough: a comparison between two techniques. Journal of Pediatric Gastroenterology and Nutrition. 2011;53:S71-72.
Vassilev ZP, Chu AF, Ruck B, et al. Adverse reactions to over-the-counter cough and cold products among children: the cases managed out of hospitals. J Clin Pharm Ther. 2009;34(3):313-8. [pmid: 19646077].
Vertigan AE, Gibson PG. The Role of Speech Pathology in the Management of Patients with Chronic Refractory Cough. Lung. 2011. [pmid: 21989493].
Vijaya Bhargava K. Medicinal uses and pharmacological properties of Crocus sativus linn (saffron). International Journal of Pharmacy and Pharmaceutical Sciences. 2011;3(SUPPL. 3):22-26.
Wacogne I. Chronic cough in children had various aetiologies and common causes of adult cough were found in < 10% of children. Evidence-Based Medicine. 2006;11(6):187. [pmid: 17213181].
Warren MD, Cooper WO. Honey improves cough in children compared to no treatment. Journal of Pediatrics. 2008;152(5):739-740. [pmid: 18410789].
Weinberger M. The habit cough syndrome. Pediatric, Allergy, Immunology, and Pulmonology. 2010;23(2):125-129.
Yamasaki A, Hanaki K, Tomita K, et al. Cough and asthma diagnosis: Physicians' diagnosis and treatment of patients complaining of acute, subacute and chronic cough in rural areas of Japan. 2010;3:101-107.
Young EC, Smith JA. Quality of life in patients with chronic cough. Ther Adv Respir Dis. 2010;4(1):49-55. [pmid: 20051447].
Zhao T, Qiu ZH, Wang L, et al. Validation of the reliability and clinical value on cough score. Respirology. 2011;16:195.
Ziment I. Controlled-release codeine in the treatment of allergic cough. Advances in Therapy. 1987;4(2):63-72.

## Study population does not have cough (KQ 1) or chronic cough (KQ 2)

Ainapure SS, Desai A, Korde K. Efficacy and safety of Ascoril in the management of cough--National Study Group report. J Indian Med Assoc. 2001;99(2):111. 114. [pmid: 11482804].
Allen CJ, Anvari M. Gastro-oesophageal reflux related cough and its response to laparoscopic fundoplication. Thorax. 1998;53(11):963-8. [pmid: 10193396].
Auffarth B, Postma DS, de Monchy JG, et al. Effects of inhaled budesonide on spirometric values, reversibility, airway responsiveness, and cough threshold in smokers with chronic obstructive lung disease. Thorax. 1991;46(5):372-7. [pmid: 2068695].
Azzopardi JF, Vanscolina AB. Clinical trial of a new anti-tussive (‘Dimyril’). Br J Clin Pract. 1964;18:213-4. [pmid: 14140732].
Banderali G, Riva E, Fiocchi A, et al. Efficacy and tolerability of levodropropizine and dropropizine in children with non-productive cough. J Int Med Res. 1995;23(3):175-83. [pmid: 7649341].
Barber CM, Curran AD, Bradshaw LM, et al. Reproducibility and validity of a Yan-style portable citric acid cough challenge. Pulm Pharmacol Ther. 2005;18(3):177-80. [pmid: 15707851].
Barnes N, Pavord I, Chuchalin A, et al. A randomized, souble-blind, placebo-controlled study of CRTH2 antagonist OC000459 in moderate persistent asthma. Clinical and Experimental Allergy. 2012;42(1):38-48. [pmid: 21762224].
Benini L, Ferrari M, Sembenini C, et al. Cough threshold in reflux oesophagitis: influence of acid and of laryngeal and oesophageal damage. Gut. 2000;46(6):762-7. [pmid: 10807885].
Berthelot J, Weibel MA. Comparative clinical evaluation of the antitussive activity of butamirate citrate linctus (Sinecod(registered trademark)) v. a codeine-containing linctus (Netux(registered trademark)). Clinical Trials Journal. 1990;27(1):50-57.
Beumer HM, Hardonk HJ, Boter J, et al. Objective evaluation of antitussive agents under clinical conditions. Respiration. 1976;33(1):9-13. [pmid: 1105726].
Bhalla P, Singh NP, Ravi K. Attenuation of angiotensin converting enzyme inhibitor induced cough by iron supplementation: role of nitric oxide. J Renin Angiotensin Aldosterone Syst. 2011. [pmid: 21421658].
Blanc FX, Macedo P, Hew M, et al. Capsaicin cough sensitivity in smokers with and without airflow obstruction. Respir Med. 2009;103(5):786-90. [pmid: 19136241].
Bossi R, Braga PC, Centanni S, et al. Antitussive activity and respiratory system effects of levodropropizine in man. Arzneimittelforschung. 1988;38(8):1159-62. [pmid: 3196411].
Calesnick B, Christensen JA. Latency of cough response as a measure of antitussive agents. Clin Pharmacol Ther. 1967;8(3):374-80. [pmid: 5338381].
Calesnick B, Vernick H. Antitussive activity of ethanol. Q J Stud Alcohol. 1971;32(2):434-41. [pmid: 4932255].
Cao H, Han M, Li X, et al. Clinical research evidence of cupping therapy in China: A systematic literature review. BMC Complementary and Alternative Medicine. 2010;10.
Catena E, Daffonchio L. Efficacy and tolerability of levodropropizine in adult patients with non-productive cough. Comparison with dextromethorphan. Pulm Pharmacol Ther. 1997;10(2):89-96. [pmid: 9425640].
Cavigioli G, Pelucchi A, Mastropasqua B, et al. Prevalence and repeatability of the cough response induced by inhalation of low chloride ion solutions in normal subjects. Monaldi Arch Chest Dis. 1995;50(5):352-5. [pmid: 8541816].
Chakrabarti A, Pandhi P, Jindal SK, et al. A comparative randomized double-blind clinical trial of hexapneumine and clistine as antitussive agents. Int J Clin Pharmacol Ther Toxicol. 1987;25(6):310-2. [pmid: 3305379].
Cho HB, Kwak HJ, Park SY, et al. Comparison of the incidence and severity of cough after alfentanil and remifentanil injection. Acta Anaesthesiol Scand. 2010;54(6):717-20. [pmid: 20085544].
Cohen BM. Respiratory and cough mechanics in antitussive trials. Responsivity of objective indices to the treatment of acute upper respiratory tract infections. Respiration. 1975;32(1):32-45. [pmid: 1090987].
Cox ID, Wallis PJ, Apps MC, et al. An electromyographic method of objectively assessing cough intensity and use of the method to assess effects of codeine on the dose-response curve to citric acid. Br J Clin Pharmacol. 1984;18(3):377-82. [pmid: 6487476].
D'Urzo A, Ferguson GT, van Noord JA, et al. Efficacy and safety of once-daily NVA237 in patients with moderate-to-severe COPDL the GLOW1 trial. Respiratory Research. 2011;12.
Damonte C, De Nadon J, Scarpazza G. Study of the spontaneous cough under a pharmacological treatment and of the cough induced by a non-specific bronchial stimulation. A simple method of cough recording. Giornale Italiano della Malattie del Torace. 1985;39(4):223-229.
Davenport PW, Bolser DC, Vickroy T, et al. The effect of codeine on the Urge-to-Cough response to inhaled capsaicin. Pulm Pharmacol Ther. 2007;20(4):338-46. [pmid: 17292647].
Davenport PW, Vovk A, Duke RK, et al. The urge-to-cough and cough motor response modulation by the central effects of nicotine. Pulm Pharmacol Ther. 2009;22(2):82-9. [pmid: 19100331].
De Castro G, Remondini R, dos Santos AZ, et al. Analysis of symptoms, clinical signs and oxygen support in patients with bronchiolitis before and after chest physiotherapy during hospitalization. Revist Paulist de Pediatria. 2011;29(4):599-605.
Dicpinigaitis PV. Short- and long-term reproducibility of capsaicin cough challenge testing. Pulm Pharmacol Ther. 2003;16(1):61-5. [pmid: 12657501].
Elliott WJ. Double-blind comparison of eprosartan and enalapril on cough and blood pressure in unselected hypertensive patients. Eprosartan Study Group. J Hum Hypertens. 1999;13(6):413-7. [pmid: 10408592].
Fontana GA, Pantaleo T, Lavorini F, et al. Repeatability of cough-related variables during fog challenges at threshold and suprathreshold stimulus intensity in humans. Eur Respir J. 1999;13(6):1447-50. [pmid: 10445625].
Fujimori K, Suzuki E, Arakawa M. Effects of oxatomide, H1-antagonist, on postinfectious chronic cough; a comparison of oxatomide combined with dextromethorphan versus dextromethorphan alone. Arerugi. 1998;47(1):48-53. [pmid: 9528165].
Fukuhara A, Saito J, Sato S, et al. Validation study of asthma screening criteria based on subjective symptoms and fractional exhaled nitric oxide. Annals of Allergy, Asthma and Immunology. 2011.
Gillissen A, Richter A, Oster H. Clinical efficacy of short-term treatment with extra-fine HFA beclomethasone dipropionate in patients with post-infectious persistent cough. J Physiol Pharmacol. Suppl 5. 2007;58(Pt 1):223-32. [pmid: 18204132].
Gupta VK. Metoclopramide aborts cough-induced headache and ameliorates cough--a pilot study. Int J Clin Pract. 2007;61(2):345-8. [pmid: 16787437].
Irifune K, Hamada H, Ito R, et al. Antitussive effect of bakumondoto a fixed kampo medicine (six herbal components) for treatment of post-infectious prolonged cough: controlled clinical pilot study with 19 patients. Phytomedicine. 2011;18(8-9):630-3. [pmid: 21514123].
Johansson A, Lowhagen O, Millqvist E, et al. Capsaicin inhalation test for identification of sensory hyperreactivity. Respir Med. 2002;96(9):731-5. [pmid: 12243320].
Johnston SL, Pattemore PK, Sanderson G, et al. Community study of role of viral infections in exacerbations of asthma in 9-11 year old children. BMJ. 1995;310(6989):1225-9. [pmid: 7767192].
Joo MJ, Au DH, Fitzgibbon ML, et al. Determinants of spirometry use and accuracy of COPD diagnosis in primary care. J Gen Intern Med. 2011;26(11):1272-7. [pmid: 21713542].
Kamin W, Kieser M. Pinimenthol(registered trademark) ointment in patients suffering from upper respiratory tract infections - A post-marketing observational study. Phytomedicine. 2007;14(12):787-791. [pmid: 17980566].
Katsardis C, Coulie PJ. Pentoxyverine effectively controls irritating cough in preschool children. Acta Therapeutica. 1992;18(1):93-101.
Katsumata U, Sekizawa K, Inoue H, et al. Inhibitory actions of procaterol, a beta-2 stimulant, on substance P-induced cough in normal subjects during upper respiratory tract infection. Tohoku J Exp Med. 1989;158(1):105-6. [pmid: 2476867].
Kelemen SA, Cseri T, Marozsan I. Graphometric analysis of cough tachogram. Acta Physiol Hung. 1987;70(2-3):323-8. [pmid: 3434311].
Kiss J, Pongor F, Nagy M. Comparative investigation of Libexin and Hydrocodin. Ther Hung. 1968;16(2):79-82. [pmid: 5666419].
Korpas J, Kelemen S. Tussiphonographic analysis of cough sound recordings performed by Schmidt-Voigt and Hirschberg and Szende. Acta Physiol Hung. 1987;70(2-3):167-70. [pmid: 3434295].
Korpas J, Salat D, Sadlonova J, et al. The sensitivity of tussiphonography for assessing the effectiveness of treatment. Bratisl Lek Listy. 2000;101(2):71-7. [pmid: 11039211].
Koskela HO, Purokivi MK, Tukiainen RM. Simultaneous versus video counting of coughs in hypertonic cough challenges. Cough. 2008;4:8. [pmid: 18782429].
Kotlar W, Casini A. Comparative trial of a new antitussive agent: Double-blind, crossover study versus dropropyzine and placebo. Today's Therapeutic Trends. 1986;4(2):1-8.
Kotlar W, Casini A. A double-blind, cross-over study of a new antitussive agent versus dropropizine and placebo. Acta Toxicologica et Therapeutica. 1987;8(2):121-129.
Kotlar W, Kotlar A, Casini A, et al. Clinical trial of efficacy and tolerance on a new substance provided with antitussive activity. Clinical Trials Journal. 1986;23(5):281-292.
Kudi K, Takasaki J, Manabe T, et al. Systemic corticosteroids and early administration of antiviral agents for pneumonia with acute wheezing due to influenza a(h1n1)pdm09 in Japan. PLoS One. 2012;7(2).
Kuhn JJ, Hendley JO, Adams KF, et al. Antitussive effect of guaifenesin in young adults with natural colds. Objective and subjective assessment. Chest. 1982;82(6):713-8. [pmid: 6754274].
Leidy NK, Rennard SI, Schmier J, et al. The breathlessness, cough, and sputum scale: the development of empirically based guidelines for interpretation. Chest. 2003;124(6):2182-91. [pmid: 14665499].
Leidy NK, Schmier JK, Jones MK, et al. Evaluating symptoms in chronic obstructive pulmonary disease: validation of the Breathlessness, Cough and Sputum Scale. Respir Med. Suppl A. 2003;97:S59-70. [pmid: 12564612].
Levesque M, Ghezzo H, L'Archeveque J, et al. Does the methacholine test reproduce symptoms?. Can Respir J. 2010;17(5):224-8. [pmid: 21037997].
Lowry R, Wood A, Higenbottam T. The effect of anticholinergic bronchodilator therapy on cough during upper respiratory tract infections. Br J Clin Pharmacol. 1994;37(2):187-91. [pmid: 8186064].
Marguet C, Dean TP, Warner JO. Soluble intercellular adhesion molecule-1 (sICAM-1) and interferon-gamma in bronchoalveolar lavage fluid from children with airway diseases. Am J Respir Crit Care Med. 2000;162(3 Pt 1):1016-22. [pmid: 10988123].
Mason NP, Barry PW, Despiau G, et al. Cough frequency and cough receptor sensitivity to citric acid challenge during a simulated ascent to extreme altitude. Eur Respir J. 1999;13(3):508-13. [pmid: 10232417].
McCool FD, Rosen MJ. Nonpharmacologic airway clearance therapies: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):250S-259S. [pmid: 16428718].
Medici TC, Shang H, Grosgurin P, et al. No demonstrable effect of sobrerol as an expectorant in patients with stable chronic bronchial diseases. Bull Eur Physiopathol Respir. 1985;21(6):477-83. [pmid: 3907738].
Millqvist E, Lowhagen O, Bende M. Quality of life and capsaicin sensitivity in patients with sensory airway hyperreactivity. Allergy. 2000;55(6):540-5. [pmid: 10858984].
Moeller A, Diefenbacher C, Lehmann A, et al. Exhaled nitric oxide distinguishes between subgroups of preschool children with respiratory symptoms. J Allergy Clin Immunol. 2008;121(3):705-9. [pmid: 18177695].
Mohar D, Berger WE, LaForce C, et al. Efficacy and tolerability study of ciclesonide nasal aerosol in patients with perennial allergic rhinitis. Allergy and Asthma Proceedings. 2012;33(1):19-26. [pmid: 22370530].
Mossberg B, Philipson K, Strandberg K, et al. Clearance by voluntary coughing and its relationship to subjective assessment and effect of intravenous bromhexine. Eur J Respir Dis. 1981;62(3):173-9. [pmid: 7308332].
Munyard P, Bush A. How much coughing is normal?. Arch Dis Child. 1996;74(6):531-4. [pmid: 8758131].
Munyard P, Busst C, Logan-Sinclair R, et al. A new device for ambulatory cough recording. Pediatr Pulmonol. 1994;18(3):178-86. [pmid: 7800435].
Murty GE, Kelly PJ, Bradley PJ. Tussometry: an objective assessment of vocal cord function. Ann Otol Rhinol Laryngol. 1993;102(10):743-7. [pmid: 8215091].
Murty GE, Kelly PJ, Veale D. Tussometry and lung function. Clin Otolaryngol Allied Sci. 1994;19(2):117-9. [pmid: 8026087].
Nagata K, Tomii K, Otsuka K, et al. Evaluation of the chronic obstructive pulmonary disease assessment test for measurement of health-related quality of life in patients with interstitial lung disease. Respirology. 2012;17(3):506-12. [pmid: 22257381].
Nejla S, Fujimura M, Kamio Y. Comparison between tidal breathing and dosimeter methods in assessing cough receptor sensitivity to capsaicin. Respirology. 2000;5(4):337-42. [pmid: 11192544].
Nesari T, Bhagwat BK, Johnson J, et al. Clinical validation of efficacy and safety of herbal cough formula: study of herbal cough syrup. J Herb Pharmacother. 2004;4(4):1-12. [pmid: 15927921].
Ntournenopoulos G, Glickman Y. Computerised lung sound monitoring to assess effictiveness of chest physiotherapy and secretion removal: a feasibility study. Physiotherapy. 2012;98(3):250-255. [pmid: 22898583].
Oduwole O, Meremikwu MM, Oyo-Ita A, et al. Honey for acute cough in children. Cochrane Database Syst Rev. 2010;(1):CD007094. [pmid: 20091616].
Paknejad O, Hojjati SA, Pazoki M. The association between methacholine challenge test and respiratory symptoms: A study on 146 patients. Tehran University Medical Journal. 2011;68(11):662-667.
Pontiroli AE, Daffonchio L. Efficacy and tolerability of levodropropizine and clobutinol in elderly patients with nonproductive cough. Clinical Drug Investigation. 1997;14(3):175-182.
Prabhu Shankar S, Chandrashekharan S, Bolmall CS, et al. Efficacy, safety and tolerability of salbutamol + guaiphenesin + bromhexine (Ascoril) expectorant versus expectorants containing salbutamol and either guaiphenesin or bromhexine in productive cough: a randomised controlled comparative study. J Indian Med Assoc. 2010;108(5):313-4. 316. 8. 320. [pmid: 21121410].
Rece CA, Cherry AC Jr., Reece AT, et al. Tape recorder for evaluation of coughs in children. Am J Dis Child. 1966;112(2):124-8. [pmid: 5943997].
Rees PJ, Clark TJ. Assessment of antitussive effects by citric acid threshold. Br J Dis Chest. 1983;77(1):94-7. [pmid: 6344901].
Roa CC Jr., Dantes RB. Clinical effectiveness of a combination of bromhexine and amoxicillin in lower respiratory tract infection. A randomized controlled trial. Arzneimittelforschung. 1995;45(3):267-72. [pmid: 7741782].
Roberts JR, Aravapalli A, Pohl D, et al. Extraesophageal gastroesophageal reflux disease (GERD) symptoms are not more frequently associated with proximal esophageal reflux than typical GERD symptoms. Dis Esophagus. 2012. pepubahead of print. [pmid: 22243631].
Rose JR. Pholcodine plus pseudoephedrine in the treatment of cough. A controlled trial. Practitioner. 1967;198(187):704-7. [pmid: 4860038].
Rostami-Hodjegan A, Abdul-Manap R, Wright CE, et al. The placebo response to citric acid-induced cough: pharmacodynamics and gender differences. Pulm Pharmacol Ther. 2001;14(4):315-9. [pmid: 11440560].
Rouhi H, Ganji F, Nasri H. Effects of ginger on the improvement of asthma [The evaluation of its' treatmental effects]. Pakistan Journal of Nutrition. 2006;5(4):373-376.
Ruel MT, Rivera JA, Santizo MC, et al. Impact of zinc supplementation on morbidity from diarrhea and respiratory infections among rural Guatemalan children. Pediatrics. 1997;99(6):808-13. [pmid: 9164774].
Saab BR, Pashayan N, El-Chemaly S, et al. Sesame oil use in ameliorating cough in children: a randomised controlled trial. Complement Ther Med. 2006;14(2):92-9. [pmid: 16765847].
Schmidt M, Thomsen M, Schmidt U. Suitability of Ive Extract for the treatment of Paudiatric Cough. Phytotherapy Research. 2012. [epub ahead of print]. [pmid: 22532491].
Schultz A, Sly PD, Zhang G, et al. Incentive device improves spacer technique but not clinical outcome in preschool children with asthma. Journal of Paediatrics and Child Health. 2012;48(1):52-56. [pmid: 22040259].
Singh P, Murty GE, Mahajan RP, et al. The tussometer: accuracy and reproducibility. Br J Anaesth. 1994;73(2):145-8. [pmid: 7917725].
Speiser BL, Spratling L. Remote afterloading brachytherapy for the local control of endobronchial carcinoma. Int J Radiat Oncol Biol Phys. 1993;25(4):579-87. [pmid: 8454476].
Stauss-Grabo M, Atiye S, Warnke A, et al. Observational study on the tolerability and safety of film-coated tablets containing ivy extract (Prospan(R) Cough Tablets) in the treatment of colds accompanied by coughing. Phytomedicine. 2011;18(6):433-6. [pmid: 21211950].
Stone RA, Barnes PJ, Chung KF. Effect of frusemide on cough responses to chloride-deficient solution in normal and mild asthmatic subjects. Eur Respir J. 1993;6(6):862-7. [pmid: 8339807].
Stott NCH, West RR. Randomised controlled trial of antibiotics in patients with cough and purulent sputum. Current Therapeutics. 1977;18(6):89-90.
Suguikawa TR, Garcia CA, Martinez EZ, et al. Cough and dyspnea during bronchoconstriction: comparison of different stimuli. Cough. 2009;5:6. [pmid: 19555484].
Szeinberg A, Tabachnik E, Rashed N, et al. Cough capacity in patients with muscular dystrophy. Chest. 1988;94(6):1232-5. [pmid: 3191765].
Thorpe CW, Toop LJ, Dawson KP. Towards a quantitative description of asthmatic cough sounds. Eur Respir J. 1992;5(6):685-92. [pmid: 1628726].
van Asperen PP, McKay KO, Mellis CM, et al. A multicentre randomized placebo-controlled double-blind study on the efficacy of Ketotifen in infants with chronic cough or wheeze. J Paediatr Child Health. 1992;28(6):442-6. [pmid: 1466940].
Varechova S, Plevkova J, Hanacek J, et al. Role of gender and pubertal stage on cough sensitivity in childhood and adolescence. J Physiol Pharmacol. Suppl 6. 2008;59:719-26. [pmid: 19218699].
Vizel E, Yigla M, Goryachev Y, et al. Validation of an ambulatory cough detection and counting application using voluntary cough under different conditions. Cough. 2010;6:3. [pmid: 20504377].
Vohra S, Saab BR. Does sesame oil reduce cough in children?: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(1):17-19.
Wong CH, Matai R, Morice AH. Cough induced by low pH. Respir Med. 1999;93(1):58-61. [pmid: 10464850].
Woodcock A, McLeod RL, Sadeh J, et al. The efficacy of a NOP1 agonist (SCH486757) in subacute cough. Lung. Suppl 1. 2010;188:S47-52. [pmid: 19937046].
Yang P, Cheville AL, Wampfler JA, et al. Quality of life and symptom burden among long-term lung cancer survivors. J Thorac Oncol. 2012;7(1):64-70. [pmid: 22134070].
Yiallouros PK, Savva SC, Kolokotroni O, et al. Low serum high-density lipoprotein cholesterol in childhood is associated with adolescent asthma. Clinical and Experimental Allergy. 2012;42(3):423-432. [pmid: 22356143].
Yoder KE, Shaffer ML, La Tournous SJ, et al. Child assessment of dextromethorphan, diphenhydramine, and placebo for nocturnal cough due to upper respiratory infection. Clin Pediatr (Phila). 2006;45(7):633-40. [pmid: 16928841].

## Study population does not have chronic cough of unknown etiology or refractory chronic cough of known etiology, or has patients with invasive respiratory tract instrumentation (KQ 2 only)

Altunaiji S, Kukuruzovic R, Curtis N, et al. Antibiotics for whooping cough (pertussis). Cochrane Database Syst Rev. 2007;(3):CD004404. [pmid: 17636756].
Altunaiji S, Kukuruzovic R, Curtis N, et al. Antibiotics for whooping cough (pertussis). Cochrane Database Syst Rev. 2005;(1):CD004404. [pmid: 15674946].
Ambrogi V, Baldi A, Schillaci O, et al. Clinical impact of extraplural pneumonectomy for malignant pleural mesothelioma. Annals of Surgical Oncology. 2012;19(5):1692-9. [pmid: 22193885].
Aubier M, Levy J, Clerici C, et al. Protective effect of theophylline on bronchial hyperresponsiveness in patients with allergic rhinitis. Am Rev Respir Dis. 1991;143(2):346-50. [pmid: 1990951].
Aylward M, Bater PA, Davies DE, et al. Clinical therapeutic evaluation of methylcysteine hydrochloride in patients with chronic obstructive bronchitis: a balanced double-blind trial with placebo control. Curr Med Res Opin. 1978;5(6):461-71. [pmid: 350498].
Birkebaek NH, Kristiansen M, Seefeldt T, et al. Bordetella pertussis and chronic cough in adults. Clin Infect Dis. 1999;29(5):1239-42. [pmid: 10524969].
Buonpensiero P, De Gregorio F, Sepe A, et al. Hyaluronic acid improves “pleasantness” and tolerability of nebulized hypertonic saline in a cohort of patients with cystic fibrosis. Adv Ther. 2010;27(11):870-8. [pmid: 20953746].
Caramia G, Gagliardini R, Ruffini E, et al. The management of cystic fibrosis with carbocysteine lysine salt: single-blind comparative study with ambroxol hydrochloride. J Int Med Res. 1995;23(4):284-93. [pmid: 7589772].
Chang AB, Lasserson TJ, Gaffney J, et al. Gastro-oesophageal reflux treatment for prolonged non-specific cough in children and adults. Cochrane Database Syst Rev. 2006;(4):CD004823. [pmid: 17054216].
Chang AB, Lasserson TJ, Kiljander TO, et al. Systematic review and meta-analysis of randomised controlled trials of gastro-oesophageal reflux interventions for chronic cough associated with gastro-oesophageal reflux. BMJ. 2006;332(7532):11-7. [pmid: 16330475].
Dettmar PW, Strugala V, Fathi H, et al. The online Cough Clinic: developing guideline-based diagnosis and advice. Eur Respir J. 2009;34(4):819-24. [pmid: 19324957].
Edwards GF, Steel AE, Scott JK, et al. S-carboxymethylcysteine in the fluidification of sputum and treatment of chronic airway obstruction. Chest. 1976;70(4):506-13. [pmid: 789027].
Fisman EZ, Grossman E, Motro M, et al. Clinical evidence of dose-dependent interaction between aspirin and angiotensin-converting enzyme inhibitors. J Hum Hypertens. 2002;16(6):379-83. [pmid: 12037691].
Freeman LW, Welton D. Effects of imagery, critical thinking, and asthma education on symptoms and mood state in adult asthma patients: a pilot study. J Altern Complement Med. 2005;11(1):57-68. [pmid: 15750364].
Gallon A. Evaluation of chest percussion in the treatment of patients with copious sputum production. Respir Med. 1991;85(1):45-51. [pmid: 2014357].
Gawchik S, Goldstein S, Prenner B, et al. Relief of cough and nasal symptoms associated with allergic rhinitis by mometasone furoate nasal spray. Ann Allergy Asthma Immunol. 2003;90(4):416-21. [pmid: 12722964].
Gebbie T, Harris EA, O'Donnell TV, et al. Multicentre, short-term therapeutic trial of disodium cromoglycate, with and without prednisone, in adults with asthma. Br Med J. 1972;4(5840):576-80. [pmid: 4629980].
Glass J, Archer LN, Adams W, et al. Nebulised cromoglycate, theophylline, and placebo in preschool asthmatic children. Arch Dis Child. 1981;56(8):648-51. [pmid: 6791596].
Gottfarb P, Brauner A. Children with persistent cough--outcome with treatment and role of Moraxella catarrhalis?. Scand J Infect Dis. 1994;26(5):545-51. [pmid: 7710536].
Hargreaves MR, Benson MK. Inhaled sodium cromoglycate in angiotensin-converting enzyme inhibitor cough. Lancet. 1995;345(8941):13-6. [pmid: 7799699].
Irwin RS, Pratter MR, Holland PS, et al. Postnasal drip causes cough and is associated with reversible upper airway obstruction. Chest. 1984;85(3):346-52. [pmid: 6697790].
Irwin RS, Zawacki JK, Wilson MM, et al. Chronic cough due to gastroesophageal reflux disease: failure to resolve despite total/near-total elimination of esophageal acid. Chest. 2002;121(4):1132-40. [pmid: 11948043].
Ishiura Y, Fujimura M, Yamamoto H, et al. Effect of an orally active Th2 cytokine inhibitor, suplatast on “atopic cough” tosilate. Arzneimittelforschung. 2008;58(6):297-302. [pmid: 18677972].
Kim CK, Callaway Z, Kim DW, et al. Eosinophil Degranulation Is More Important than Eosinophilia in Identifying Asthma in Chronic Cough. J Asthma. 2011. [pmid: 22022864].
Kim SH, Jeong JH, Kwak HJ, et al. Measurement of nasal nitric oxide is useful for the diagnosis of sinusitis-induced prolonged cough. Tohoku J Exp Med. 2011;223(2):145-51. [pmid: 21307634].
Kinoshita M, Lee SH, Hang LW, et al. Efficacy and safety of indacaterol 150 and 300 (mu)g in chronic obstructive pulmonary disease patients from six Asian areas including Japan: a 12-week, placebo-controlled study. Respirology. 2012;17(2):379-389. [pmid: 22122202].
Kivastik J, Gibson AM, Primhak RA. Methacholine challenge in pre-school children--which outcome measure?. Respir Med. 2007;101(12):2555-60. [pmid: 17720470].
Kivastik J, Gibson AM, Primhak RA. Feasibility of shortened methacholine challenge in preschool children. Pediatr Pulmonol. 2006;41(2):146-50. [pmid: 16353178].
Kooi EM, Schokker S, Marike Boezen H, et al. Fluticasone or montelukast for preschool children with asthma-like symptoms: Randomized controlled trial. Pulm Pharmacol Ther. 2008;21(5):798-804. [pmid: 18647656].
Korpas J, Vrabec M, Sadlonova J, et al. Analysis of the cough sound frequency in adults and children with bronchial asthma. Acta Physiol Hung. 2003;90(1):27-34. [pmid: 12666872].
Kowal K, Bodzenta-Lukaszyk A, Zukowski S. Exhaled nitric oxide in evaluation of young adults with chronic cough. J Asthma. 2009;46(7):692-8. [pmid: 19728207].
Lalloo UG, Lim S, DuBois R, et al. Increased sensitivity of the cough reflex in progressive systemic sclerosis patients with interstitial lung disease. Eur Respir J. 1998;11(3):702-5. [pmid: 9596124].
Laube BL, Auci RM, Shields DE, et al. Effect of rhDNase on airflow obstruction and mucociliary clearance in cystic fibrosis. Am J Respir Crit Care Med. 1996;153(2):752-60. [pmid: 8564129].
Leidy NK, Wilcox TK, Jones PW, et al. Development of the EXAcerbations of Chronic Obstructive Pulmonary Disease Tool (EXACT): a patient-reported outcome (PRO) measure. Value Health. 2010;13(8):965-75. [pmid: 20659270].
Li AM, Lex C, Zacharasiewicz A, et al. Cough frequency in children with stable asthma: correlation with lung function, exhaled nitric oxide, and sputum eosinophil count. Thorax. 2003;58(11):974-8. [pmid: 14586052].
Li AM, Tsang TW, Chan DF, et al. Cough frequency in children with mild asthma correlates with sputum neutrophil count. Thorax. 2006;61(9):747-50. [pmid: 16670174].
Lorin MI, Denning CR. Evaluation of postural drainage by measurement of sputum volume and consistency. Am J Phys Med. 1971;50(5):215-9. [pmid: 5113410].
Luque CA, Vazquez Ortiz M. Treatment of ACE inhibitor-induced cough. Pharmacotherapy. 1999;19(7):804-10. [pmid: 10417028].
Mackay TW, Fitzpatrick MF, Douglas NJ. Non-adrenergic, non-cholinergic nervous system and overnight airway calibre in asthmatic and normal subjects. Lancet. 1991;338(8778):1289-92. [pmid: 1682685].
Macklem PT, Fraser RG, Brown WG. Bronchial pressure measurement in emphysema and bronchitis. J Clin Invest. 1965;44:897-905. [pmid: 14322023].
Malmberg LP, Pelkonen A, Hakulinen A, et al. Intraindividual variability of infant whole-body plethysmographic measurements: effects of age and disease. Pediatr Pulmonol. 1999;28(5):356-62. [pmid: 10536067].
Marchal F, Schweitzer C, Moreau-Colson C. Respiratory impedance response to a deep inhalation in children with history of cough or asthma. Pediatr Pulmonol. 2002;33(6):411-8. [pmid: 12001273].
Martinez-Garcia MA, Perpina-Tordera M, Roman-Sanchez P, et al. Inhaled steroids improve quality of life in patients with steady-state bronchiectasis. Respir Med. 2006;100(9):1623-32. [pmid: 16434174].
Martinez-Garcia MA, Perpina-Tordera M, Roman-Sanchez P, et al. Quality-of-life determinants in patients with clinically stable bronchiectasis. Chest. 2005;128(2):739-45. [pmid: 16100162].
Matos S, Birring SS, Pavord ID, et al. Detection of cough signals in continuous audio recordings using hidden Markov models. IEEE Trans Biomed Eng. 2006;53(6):1078-83. [pmid: 16761835].
McEwan JR, Choudry NB, Fuller RW. The effect of sulindac on the abnormal cough reflex associated with dry cough. J Pharmacol Exp Ther. 1990;255(1):161-4. [pmid: 2213552].
McGarvey LP, Savage DA, Feeney SA, et al. Is there an association between angiotensin-converting enzyme gene variants and chronic nonproductive cough?. Chest. 2000;118(4):1091-4. [pmid: 11035682].
Mitchell C, Miles J. Lower respiratory tract symptoms in Queensland schoolchildren. The questionnaire: its reliability and validity. Aust N Z J Med. 1983;13(3):264-9. [pmid: 6579940].
Miyashita N, Fukano H, Yoshida K, et al. Chlamydia pneumoniae infection in adult patients with persistent cough. J Med Microbiol. 2003;52(Pt 3):265-9. [pmid: 12621093].
Mochizuki H, Arakawa H, Tokuyama K, et al. Bronchial sensitivity and bronchial reactivity in children with cough variant asthma. Chest. 2005;128(4):2427-34. [pmid: 16236905].
Moroni M, Porta C, Gualtieri G, et al. Inhaled sodium cromoglycate to treat cough in advanced lung cancer patients. Br J Cancer. 1996;74(2):309-11. [pmid: 8688342].
Nobata K, Fujimura M, Tsuji H, et al. Longitudinal changes of pulmonary function and bronchial responsiveness in cough-variant asthma treated with bronchodilators alone. Allergy Asthma Proc. 2006;27(6):479-85. [pmid: 17176782].
Oldini C, Vecchi E. Double-blind investigation of the antitussive effectiveness of cloperastine. Current Therapeutic Research - Clinical and Experimental. 1987;42(1):99-105.
Pacheco A, Faro V, Cobeta I, et al. Gastro-oesophageal reflux, eosinophilic airway inflammation and chronic cough. Respirology. 2011;16(6):994-9. [pmid: 21651646].
Park SW, Lee YM, Jang AS, et al. Development of chronic airway obstruction in patients with eosinophilic bronchitis: a prospective follow-up study. Chest. 2004;125(6):1998-2004. [pmid: 15189914].
Paul IM, Beiler J, McMonagle A, et al. Effect of honey, dextromethorphan, and no treatment on nocturnal cough and sleep quality for coughing children and their parents. Arch Pediatr Adolesc Med. 2007;161(12):1140-6. [pmid: 18056558].
Paul IM, Beiler JS, King TS, et al. Vapor rub, petrolatum, and no treatment for children with nocturnal cough and cold symptoms. Pediatrics. 2010;126(6):1092-9. [pmid: 21059712].
Paul IM, Shaffer ML, Yoder KE, et al. Dose-response relationship with increasing doses of dextromethorphan for children with cough. Clin Ther. 2004;26(9):1508-14. [pmid: 15531013].
Paul IM, Yoder KE, Crowell KR, et al. Effect of dextromethorphan, diphenhydramine, and placebo on nocturnal cough and sleep quality for coughing children and their parents. Pediatrics. 2004;114(1):e85-90. [pmid: 15231978].
Petty TL. The National Mucolytic Study. Results of a randomized, double-blind, placebo-controlled study of iodinated glycerol in chronic obstructive bronchitis. Chest. 1990;97(1):75-83. [pmid: 2403903].
Redey T, Skoda E. Clinical use of Libexin, a new peripheral antitussive. Ther Hung. 1967;15(3):117-9. [pmid: 4866485].
Robinson M, Hemming AL, Moriarty C, et al. Effect of a short course of rhDNase on cough and mucociliary clearance in patients with cystic fibrosis. Pediatr Pulmonol. 2000;30(1):16-24. [pmid: 10862158].
Robinson M, Regnis JA, Bailey DL, et al. Effect of hypertonic saline, amiloride, and cough on mucociliary clearance in patients with cystic fibrosis. Am J Respir Crit Care Med. 1996;153(5):1503-9. [pmid: 8630593].
Rusconi F, Panisi C, Dellepiane RM, et al. Pulmonary and sinus diseases in primary humoral immunodeficiencies with chronic productive cough. Arch Dis Child. 2003;88(12):1101-5. [pmid: 14670780].
Schaefer MK, Shehab N, Cohen AL, et al. Adverse events from cough and cold medications in children. Pediatrics. 2008;121(4):783-7. [pmid: 18227192].
Schulz M, Hammerlein A, Hinkel U, et al. Safety and usage pattern of an over-the-counter ambroxol cough syrup: a community pharmacy-based cohort study. Int J Clin Pharmacol Ther. 2006;44(9):409-21. [pmid: 16995329].
Serrao N, Magnani R, Libardi S, et al. The effect of low-intensity laser in a patient with chronic obstructive pulmonary disease during respiratory therapy. Lasers in Surgery and Medicine. 2012;44:54.
Shadkam MN, Mozaffari-Khosravi H, Mozayan MR. A comparison of the effect of honey, dextromethorphan, and diphenhydramine on nightly cough and sleep quality in children and their parents. J Altern Complement Med. 2010;16(7):787-93. [pmid: 20618098].
Sundar KM, Daly SE, Pearce MJ, et al. Chronic cough and obstructive sleep apnea in a community-based pulmonary practice. Cough. 2010;6(1):2. [pmid: 20398333].
Suwanjutha S, Chantarojanasiri T. The role of ketotifen in children with recurrent bronchitis. J Int Med Res. 1985;13(1):24-30. [pmid: 3979657].
Tamaoki J, Yokohori N, Tagaya E, et al. Comparable effect of a leukotriene receptor antagonist and long-acting beta-adrenergic agonist in cough variant asthma. Allergy Asthma Proc. 2010;31(5):78-84. [pmid: 20929598].
Townley RG, Bronstein SB. A double blind clinical evaluation of glyceryl guaiacolate. Ann Allergy. 1963;21:683-91. [pmid: 14085798].
Watson RR, Zibadi S, Rafatpanah H, et al. Oral administration of the purple passion fruit peel extract reduces wheeze and cough and improves shortness of breath in adults with asthma. Nutr Res. 2008;28(3):166-71. [pmid: 19083404].
Wojcicki J, Szwed G, Drozdowska-Ksiazek D. The antitussive and expectorant drug Duopect evaluated by the preferential test. Arch Immunol Ther Exp (Warsz). 1976;24(4):549-52. [pmid: 793565].

## No intervention of interest OR the intervention is intended to treat the underlying etiology

Allen CJ, Anvari M. Does laparoscopic fundoplication provide long-term control of gastroesophageal reflux related cough?. Surg Endosc. 2004;18(4):633-7. [pmid: 15026893].
Allen CJ, Anvari M. Preoperative symptom evaluation and esophageal acid infusion predict response to laparoscopic Nissen fundoplication in gastroesophageal reflux patients who present with cough. Surg Endosc. 2002;16(7):1037-41. [pmid: 12165818].
Anbar RD. Hypnosis in pediatrics: applications at a pediatric pulmonary center. BMC Pediatr. 2002;2:11. [pmid: 12460456].
Anbar RD, Hall HR. Childhood habit cough treated with self-hypnosis. J Pediatr. 2004;144(2):213-7. [pmid: 14760264].
Baldi F, Cappiello R, Cavoli C, et al. Proton pump inhibitor treatment of patients with gastroesophageal reflux-related chronic cough: a comparison between two different daily doses of lansoprazole. World J Gastroenterol. 2006;12(1):82-8. [pmid: 16440422].
Bede O, Szenasi Z, Danka J, et al. Toxocariasis associated with chronic cough in childhood: a longitudinal study in Hungary. J Helminthol. 2008;82(4):357-63. [pmid: 18752712].
Blager FB, Gay ML, Wood RP. Voice therapy techniques adapted to treatment of habit cough: a pilot study. J Commun Disord. 1988;21(5):393-400. [pmid: 3183084].
Bucca CB, Culla B, Guida G, et al. Unexplained chronic cough and vitamin B-12 deficiency. Am J Clin Nutr. 2011;93(3):542-8. [pmid: 21248188].
Chan PW, Debruyne JA. Inhaled nedocromil sodium for persistent cough in children. Med J Malaysia. 2001;56(4):408-13. [pmid: 12014758].
Chang A, Marchant JM, McKean M, et al. Inhaled cromones for prolonged non-specific cough in children. Cochrane Database Syst Rev. 2004;(2):CD004436. [pmid: 15106252].
Chang AB, Gaffney JT, Eastburn MM, et al. Cough quality in children: a comparison of subjective vs. bronchoscopic findings. Respir Res. 2005;6:3. [pmid: 15638942].
Chang AB, Halstead RA, Petsky HL. Methylxanthines for prolonged non-specific cough in children. Cochrane Database Syst Rev. 2005;(3):CD005310. [pmid: 16034969].
Chang AB, McKean M, Morris P. Inhaled anti-cholinergics for prolonged non-specific cough in children. Cochrane Database Syst Rev. 2004;(1):CD004358. [pmid: 14974067].
Chang AB, Peake J, McElrea MS. Anti-histamines for prolonged non-specific cough in children. Cochrane Database Syst Rev. 2008;(2):CD005604. [pmid: 18425925].
Chang AB, Phelan PD, Carlin JB, et al. A randomised, placebo controlled trial of inhaled salbutamol and beclomethasone for recurrent cough. Arch Dis Child. 1998;79(1):6-11. [pmid: 9771244].
Chang AB, Winter D, Acworth JP. Leukotriene receptor antagonist for prolonged non-specific cough in children. Cochrane Database Syst Rev. 2006;(2):CD005602. [pmid: 16625643].
Charpin J, Weibel MA. Comparative evaluation of the antitussive activity of butamirate citrate linctus versus clobutinol syrup. Respiration. 1990;57(4):275-9. [pmid: 2095610].
Cheriyan S, Greenberger PA, Patterson R. Outcome of cough variant asthma treated with inhaled steroids. Ann Allergy. 1994;73(6):478-80. [pmid: 7998659].
Chernish SM, Lewis G, Kraft B, et al. Clinical evaluation of a new antitussive preparation. Ann Allergy. 1963;21:677-82. [pmid: 14085797].
Clough JB, Williams JD, Holgate ST. Profile of bronchial responsiveness in children with respiratory symptoms. Arch Dis Child. 1992;67(5):574-9. [pmid: 1599291].
Clough JB, Williams JD, Holgate ST. Effect of atopy on the natural history of symptoms, peak expiratory flow, and bronchial responsiveness in 7- and 8-year-old children with cough and wheeze. A 12-month longitudinal study. [published errarum appears in Am Rev Respir Dis 1992 Aug;146(2):540]. Am Rev Respir Dis. 1991;143(4 Pt 1):755-60. [pmid: 2008988].
Cockcroft DW, Killian DN, Mellon JJ, et al. Bronchial reactivity to inhaled histamine: a method and clinical survey. Clin Allergy. 1977;7(3):235-43. [pmid: 908121].
Cohen BM. Maximum voluntary cough ratios reflect antitussive activity of inhaled albuterol. N J Med. 1992;89(8):587-91. [pmid: 1513504].
Davies MJ, Fuller P, Picciotto A, et al. Persistent nocturnal cough: randomised controlled trial of high dose inhaled corticosteroid. Arch Dis Child. 1999;81(1):38-44. [pmid: 10373132].
Desjardins A, de Luca S, Cartier A, et al. Nonspecific bronchial hyperresponsiveness to inhaled histamine and hyperventilation of cold dry air in subjects with respiratory symptoms of uncertain etiology. Am Rev Respir Dis. 1988;137(5):1020-5. [pmid: 3195801].
Dicpinigaitis PV, Dobkin JB, Reichel J. Antitussive effect of the leukotriene receptor antagonist zafirlukast in subjects with cough-variant asthma. J Asthma. 2002;39(4):291-7. [pmid: 12095178].
Doan T, Patterson R, Greenberger PA. Cough variant asthma: usefulness of a diagnostic-therapeutic trial with prednisone. Ann Allergy. 1992;69(6):505-9. [pmid: 1471782].
Ellul-Micallef R. Effect of terbutaline sulphate in chronic “allergic” cough. Br Med J (Clin Res Ed). 1983;287(6397):940-3. [pmid: 6412896].
Evald T, Munch EP, Kok-Jensen A. Chronic non-asthmatic cough is not affected by inhaled beclomethasone dipropionate. A controlled double blind clinical trial. Allergy. 1989;44(7):510-4. [pmid: 2683836].
Eysink PE, Bottema BJ, ter Riet G, et al. Coughing in pre-school children in general practice: when are RAST's for inhalation allergy indicated?. Pediatr Allergy Immunol. 2004;15(5):394-400. [pmid: 15482513].
Faruqi S, Wilmot R, Wright C, et al. Serum LDH in chronic cough: a potential marker of airway inflammation. Clin Respir J. 2012;6(2):81-7. [pmid: 21651741].
Fathi H, Moon T, Donaldson J, et al. Cough in adult cystic fibrosis: diagnosis and response to fundoplication. Cough. 2009;5:1. [pmid: 19149907].
Field SK, Conley DP, Thawer AM, et al. Assessment and management of patients with chronic cough by Certified Respiratory Educators: a randomized controlled trial. Can Respir J. 2009;16(2):49-54. [pmid: 19399308].
Fogari R, Zoppi A, Mugellini A, et al. Difference in incidence of cough induced by imidapril and ramipril: Role of prostaglandin synthesis inhibition. Biomedicine and Aging Pathology. 2011;1(2):73-77.
Fogari R, Zoppi A, Mugellini A, et al. Effects of amlodipine, nifedipine GITS, and indomethacin on angiotensin- converting enzyme inhibitor-induced cough: A randomized, placebo-controlled, double-masked, crossover study. Current Therapeutic Research - Clinical and Experimental. 1999;60(3):121-128.
Fogari R, Zoppi A, Tettamanti F, et al. Effects of nifedipine and indomethacin on cough induced by angiotensin-converting enzyme inhibitors: a double-blind, randomized, cross-over study. J Cardiovasc Pharmacol. 1992;19(5):670-3. [pmid: 1381763].
Fogleman CD. GERD treatment for chronic nonspecific cough in children and adults. Am Fam Physician. 2011;84(5):502-4. [pmid: 21888300].
Galvez RA, McLaughlin FJ, Levison H. The role of the methacholine challenge in children with chronic cough. J Allergy Clin Immunol. 1987;79(2):331-5. [pmid: 3546464].
Ghafouri MA, Patil KD, Kass I. Sputum changes associated with the use of ipratropium bromide. Chest. 1984;86(3):387-93. [pmid: 6236043].
Gibson PG, Hargreave FE, Girgis-Gabardo A, et al. Chronic cough with eosinophilic bronchitis: examination for variable airflow obstruction and response to corticosteroid. Clin Exp Allergy. 1995;25(2):127-32. [pmid: 7750004].
Hannaway PJ, Hopper GD. Cough variant asthma in children. JAMA. 1982;247(2):206-8. [pmid: 7053462].
Hedman J, Poussa T, Nieminen MM. A rapid dosimetric methacholine challenge in asthma diagnostics: a clinical study of 230 patients with dyspnoea, wheezing or a cough of unknown cause. Respir Med. 1998;92(1):32-9. [pmid: 9519222].
Hersh MJ, Sayuk GS, Gyawali CP. Long-term therapeutic outcome of patients undergoing ambulatory pH monitoring for chronic unexplained cough. J Clin Gastroenterol. 2010;44(4):254-60. [pmid: 19826278].
Hirsch SR, Viernes PF, Kory RC. Clinical and physiological evaluation of mucolytic agents nebulized with soproterenol: 10 per cent N-acetylcysteine verus 10 per cent 2-mercaptoethane sulphonate. Thorax. 1970;25(6):737-43. [pmid: 4925508].
Hsiue TR, Hsieh AL, Chang HY, et al. Bronchoprovocation test by forced oscillation technique: airway hyperresponsiveness in chronic cough and psychogenic dyspnea subjects. J Formos Med Assoc. 1993;92(3):231-6. [pmid: 8102275].
Ing AJ, Ngu MC, Breslin AB. Pathogenesis of chronic persistent cough associated with gastroesophageal reflux. Am J Respir Crit Care Med. 1994;149(1):160-7. [pmid: 8111576].
Irwin RS, Corrao WM, Pratter MR. Chronic persistent cough in the adult: the spectrum and frequency of causes and successful outcome of specific therapy. Am Rev Respir Dis. 1981;123(4 Pt 1):413-7. [pmid: 7224353].
Ishiura Y, Fujimura M, Yamamori C, et al. Thromboxane antagonism and cough in chronic bronchitis. Ann Med. 2003;35(2):135-9. [pmid: 12795341].
Joo JH, Park SJ, Park SW, et al. Clinical features of eosinophilic bronchitis. Korean J Intern Med. 2002;17(1):31-7. [pmid: 12014210].
Kamano H, Mori T, Maeta H, et al. Analysis of Bordetella pertussis agglutinin titers during an outbreak of pertussis at a university in Japan. Jpn J Infect Dis. 2010;63(2):108-12. [pmid: 20332572].
Kastelik JA, Aziz I, Ojoo JC, et al. Investigation and management of chronic cough using a probability-based algorithm. Eur Respir J. 2005;25(2):235-43. [pmid: 15684286].
Kawai S, Baba K, Matsubara A, et al. The efficacy of montelukast and airway mast cell profiles in patients with cough variant asthma. J Asthma. 2008;45(3):243-50. [pmid: 18415834].
Kiljander TO, Salomaa ER, Hietanen EK, et al. Chronic cough and gastro-oesophageal reflux: a double-blind placebo-controlled study with omeprazole. Eur Respir J. 2000;16(4):633-8. [pmid: 11106204].
Kita T, Fujimura M, Ogawa H, et al. Antitussive effects of the leukotriene receptor antagonist montelukast in patients with cough variant asthma and atopic cough. Allergol Int. 2010;59(2):185-92. [pmid: 20299826].
Konig P. Hidden asthma in childhood. Am J Dis Child. 1981;135(11):1053-5. [pmid: 7294009].
Lee J, Kim M, Kim JH, et al. A cheaper, faster way to resolve chronic cough. J Fam Pract. 2007;56(8):641-6. [pmid: 17669289].
Lieder A, Issing W. Treatment for resilient cough owing to laryngopharyngeal reflux with a combination of proton pump inhibitor and Gaviscon® Advance: how we do it. Clinical Otolaryngology. 2011;36(6):583-7. [pmid: 22212545].
Liu SF, Lin MC, Chang HW. Relationship of allergic degree and PC20 level in adults with positive methacholine challenge test. Respiration. 2005;72(6):612-6. [pmid: 16355001].
Malmberg LP, Pelkonen AS, Haahtela T, et al. Exhaled nitric oxide rather than lung function distinguishes preschool children with probable asthma. Thorax. 2003;58(6):494-9. [pmid: 12775859].
Marguet C, Jouen-Boedes F, Dean TP, et al. Bronchoalveolar cell profiles in children with asthma, infantile wheeze, chronic cough, or cystic fibrosis. Am J Respir Crit Care Med. 1999;159(5 Pt 1):1533-40. [pmid: 10228122].
Mulrennan S, Wright C, Thompson R, et al. Effect of salbutamol on smoking related cough. Pulm Pharmacol Ther. 2004;17(3):127-31. [pmid: 15123221].
Mund E, Christensson B, Gronneberg R, et al. Noneosinophilic CD4 lymphocytic airway inflammation in menopausal women with chronic dry cough. Chest. 2005;127(5):1714-21. [pmid: 15888851].
Nennig ME, Shinefield HR, Edwards KM, et al. Prevalence and incidence of adult pertussis in an urban population. JAMA. 1996;275(21):1672-4. [pmid: 8637142].
Niimi A, Nguyen LT, Usmani O, et al. Reduced pH and chloride levels in exhaled breath condensate of patients with chronic cough. Thorax. 2004;59(7):608-12. [pmid: 15223872].
Nishikawa M, Suzuki S, Miyazawa N, et al. Serum level of eosinophil cationic protein in patients with chronic cough: relationship to blood eosinophils and airway hyperresponsiveness. J Asthma. 1998;35(2):219-24. [pmid: 9576148].
Nishimura H, Mochizuki H, Tokuyama K, et al. Relationship between bronchial hyperresponsiveness and development of asthma in children with chronic cough. Pediatr Pulmonol. 2001;31(6):412-8. [pmid: 11389572].
Nogami H, Shoji S, Nishima S. Exhaled nitric oxide as a simple assessment of airway hyperresponsiveness in bronchial asthma and chronic cough patients. J Asthma. 2003;40(6):653-9. [pmid: 14579996].
O'Connell F, Springall DR, Moradoghli-Haftvani A, et al. Abnormal intraepithelial airway nerves in persistent unexplained cough?. Am J Respir Crit Care Med. 1995;152(6 Pt 1):2068-75. [pmid: 8520777].
Ogawa H, Fujimura M, Takeuchi Y, et al. Sensitization to Bjerkandera adusta enhances severity of cough symptom in patients with fungus-associated chronic cough (FACC). Med Mycol J. 2011;52(3):205-12. [pmid: 21891982].
Ogawa H, Fujimura M, Takeuchi Y, et al. Is Bjerkandera adusta Important to fungus-associated chronic cough as an allergen? Eight cases' reports. J Asthma. 2009;46(8):849-55. [pmid: 19863292].
Ogawa H, Fujimura M, Takeuchi Y, et al. The importance of basidiomycetous fungi cultured from the sputum of chronic idiopathic cough: a study to determine the existence of recognizable clinical patterns to distinguish CIC from non-CIC. Respir Med. 2009;103(10):1492-7. [pmid: 19473825].
Oh MJ, Lee JY, Lee BJ, et al. Exhaled nitric oxide measurement is useful for the exclusion of nonasthmatic eosinophilic bronchitis in patients with chronic cough. Chest. 2008;134(5):990-5. [pmid: 18583518].
Otsuka K, Niimi A, Matsumoto H, et al. Plasma substance p levels in patients with persistent cough. Respiration. 2011;82(5):431-8. [pmid: 21846969].
Pawar S, Lim HJ, Gill M, et al. Treatment of postnasal drip with proton pump inhibitors: a prospective, randomized, placebo-controlled study. Am J Rhinol. 2007;21(6):695-701. [pmid: 18201449].
Pizzichini MM, Pizzichini E, Parameswaran K, et al. Nonasthmatic chronic cough: No effect of treatment with an inhaled corticosteroid in patients without sputum eosinophilia. Can Respir J. 1999;6(4):323-30. [pmid: 10463960].
Poe RH, Kallay MC. Chronic cough and gastroesophageal reflux disease: experience with specific therapy for diagnosis and treatment. Chest. 2003;123(3):679-84. [pmid: 12628862].
Ponsioen BP, Hop WC, Vermue NA, et al. Efficacy of fluticasone on cough: a randomised controlled trial. Eur Respir J. 2005;25(1):147-52. [pmid: 15640336].
Pornsuriyasak P, Charoenpan P, Vongvivat K, et al. Inhaled corticosteroid for persistent cough following upper respiratory tract infection. Respirology. 2005;10(4):520-4. [pmid: 16135178].
Pounsford JC, Birch MJ, Saunders KB. Effect of bronchodilators on the cough response to inhaled citric acid in normal and asthmatic subjects. Thorax. 1985;40(9):662-7. [pmid: 2932814].
Qiu Z, Wei W, Yu L, et al. Efficacy and safety of modified sequential three-step empirical therapy for chronic cough. Respirology. 2010;15(5):830-836. [pmid: 20546197].
Rafferty P, Jackson L, Smith R, et al. Terfenadine, a potent histamine H1-receptor antagonist in the treatment of grass pollen sensitive asthma. Br J Clin Pharmacol. 1990;30(2):229-35. [pmid: 1976343].
Ratner PH, Findlay SR, Hampel F Jr., et al. A double-blind, controlled trial to assess the safety and efficacy of azelastine nasal spray in seasonal allergic rhinitis. J Allergy Clin Immunol. 1994;94(5):818-25. [pmid: 7963150].
Robson RA, Taylor BJ, Taylor B. Sodium cromoglycate: spincaps or metered dose aerosol. Br J Clin Pharmacol. 1981;11(4):383-4. [pmid: 6789851].
Rubin BK. An in vitro comparison of the mucoactive properties of guaifenesin, iodinated glycerol, surfactant, and albuterol. Chest. 1999;116(1):195-200. [pmid: 10424525].
Rubin BK, Ramirez O, Ohar JA. Iodinated glycerol has no effect on pulmonary function, symptom score, or sputum properties in patients with stable chronic bronchitis. Chest. 1996;109(2):348-52. [pmid: 8620704].
Ryan NM, Vertigan AE, Gibson PG. Chronic cough and laryngeal dysfunction improve with specific treatment of cough and paradoxical vocal fold movement. Cough. 2009;5:4. [pmid: 19292930].
Sagara H, Yukawa T, Kashima R, et al. Effects of pranlukast hydrate on airway hyperresponsiveness in non-asthmatic patients with Japanese cedar pollinosis. Allergol Int. 2009;58(2):277-87. [pmid: 19390239].
Saito Y, Azuma A, Morimoto T, et al. Tiotropium ameliorates symptoms in patients with chronic airway mucus hypersecretion which is resistant to macrolide therapy. Intern Med. 2008;47(7):585-91. [pmid: 18379141].
Sheikh A, Nolan D, Greenstone M. Long-acting beta-2-agonists for bronchiectasis. Cochrane Database Syst Rev. 2001;(4):CD002155. [pmid: 11687145].
Shioya T, Ito N, Sasaki M, et al. Cough threshold for capsaicin increases by azelastine in patients with cough-variant asthma. Pulm Pharmacol. 1996;9(1):59-62. [pmid: 8843511].
Shioya T, Ito N, Watanabe A, et al. Antitussive effect of azelastine hydrochloride in patients with bronchial asthma. Arzneimittelforschung. 1998;48(2):149-53. [pmid: 9541725].
Shioya T, Satake M, Kagaya M, et al. Antitussive effects of the H1-receptor antagonist epinastine in patients with atopic cough (eosinophilic bronchitis). Arzneimittelforschung. 2004;54(4):207-12. [pmid: 15146933].
Shioya T, Satake M, Sano M, et al. Effect of suplatast tosilate, a Th2 cytokine inhibitor, on cough variant asthma. Eur J Clin Pharmacol. 2002;58(3):171-6. [pmid: 12107601].
Sipp JA, Haver KE, Masek BJ, et al. Botulinum toxin A: a novel adjunct treatment for debilitating habit cough in children. Ear Nose Throat J. 2007;86(9):570-2. [pmid: 17970150].
Spector SL, Tan RA. Effectiveness of montelukast in the treatment of cough variant asthma. Ann Allergy Asthma Immunol. 2004;93(3):232-6. [pmid: 15478381].
Takemura M, Niimi A, Matsumoto H, et al. Clinical, physiological and anti-inflammatory effect of montelukast in patients with cough variant asthma. Respiration. 2012;83(4):308-15. [pmid: 22094623].
Theodore AC, Tseng CH, Li N, et al. Correlation of cough with disease activity and treatment with cyclosphosphamide in scleroderma interstitial lung disease: findings from the Scleroderma Lung Study. Chest. 2011. [epub ahead of print]. [pmid: 22156609].
Vardar R, Sweis R, Anggiansah A, et al. Upper esophageal sphincter and esophageal motility in patients with chronic cough and reflux: assessment by high-resolution manometry. Dis Esophagus. 2012. [epub ahead of print]. [pmid: 22591118].
Waring JP, Lacayo L, Hunter J, et al. Chronic cough and hoarseness in patients with severe gastroesophageal reflux disease. Diagnosis and response to therapy. Dig Dis Sci. 1995;40(5):1093-7. [pmid: 7729270].
Yu L, Qiu Z, Lu H, et al. Clinical benefit of sequential three-step empirical therapy in the management of chronic cough. Respirology. 2008;13(3):353-8. [pmid: 18399856].

## No outcomes of interest

Abborr J, Holt A, Morton AM, et al. Patient indicators of a pulmonary exacerbation: preliminary reports from school aged children map onto those of adults. K Cyst Fibros. 2012;11(3):180-6. [pmid: 22172941].
Al-Mobeireek AF, Al-Sarhani A, Al-Amri S, et al. Chronic cough at a non-teaching hospital: Are extrapulmonary causes overlooked?. Respirology. 2002;7(2):141-6. [pmid: 11985737].
Ambrosino N, Callegari G, Galloni C, et al. Clinical evaluation of oscillating positive expiratory pressure for enhancing expectoration in diseases other than cystic fibrosis. Monaldi Arch Chest Dis. 1995;50(4):269-75. [pmid: 7550205].
Anderson-james S, Mewcombe PA, Marchant JM, et al. Development of a children's acute cough specific quality of life quationnaire (PAC-QOL). Respirology. 2012;17:76.
Aquilina R, Bergero F, Noceti P, et al. Double blind study with neltenexine vs placebo in patients affected by acute and chronic lung diseases. Minerva Pneumologica. 2001;40(2):77-82.
Asilsoy S, Bayram E, Agin H, et al. Evaluation of chronic cough in children. Chest. 2008;134(6):1122-8. [pmid: 18689594].
Avidan B, Sonnenberg A, Schnell TG, et al. Temporal associations between coughing or wheezing and acid reflux in asthmatics. Gut. 2001;49(6):767-72. [pmid: 11709509].
Avital A, Uwyyed K, Berkman N, et al. Exhaled nitric oxide and asthma in young children. Pediatr Pulmonol. 2001;32(4):308-13. [pmid: 11568992].
Ayik SO, Basoglu OK, Erdinc M, et al. Eosinophilic bronchitis as a cause of chronic cough. Respir Med. 2003;97(6):695-701. [pmid: 12814157].
Aylward M, Maddock J, Davies DE, et al. Dextromethorphan and codeine: comparison of plasma kinetics and antitussive effects. Eur J Respir Dis. 1984;65(4):283-91. [pmid: 6539224].
Badier M, Guillot C, Dubus JC. Bronchial challenge with carbachol in 3-6-year-old children: body plethysmography assessments. Pediatr Pulmonol. 1999;27(2):117-23. [pmid: 10088935].
Bai J, Peat JK, Berry G, et al. Questionnaire items that predict asthma and other respiratory conditions in adults. Chest. 1998;114(5):1343-8. [pmid: 9824012].
Bailly C, Crenesse D, Albertini M. Evaluation of impulse oscillometry during bronchial challenge testing in children. Pediatr Pulmonol. 2011. [pmid: 21634033].
Bakirtas A, Turktas I. Methacholine and adenosine 5'-monophosphate challenges in preschool children with cough-variant and classic asthma. Pediatr Pulmonol. 2007;42(10):973-9. [pmid: 17722054].
Bakker EM, van der Meijden JC, Nieuwhof EM, et al. Determining presence of lung disease in young children with cystic fibrosis: lung clearance index, oxygen saturation and cough frequency. J Cyst Fibros. 2012;11(3):223-30. [pmid: 22265603].
Barbara AM, Loeb M, Dolovich L, et al. Agreement between self-report and medical records on signs and symptoms of respiratory illness. Prim Care Respir J. 2012;21(2):145-52. [pmid: 22273629].
Barnes TW, Afessa B, Swanson KL, et al. The clinical utility of flexible bronchoscopy in the evaluation of chronic cough. Chest. 2004;126(1):268-72. [pmid: 15249470].
Bateman JR, Newman SP, Daunt KM, et al. Regional lung clearance of excessive bronchial secretions during chest physiotherapy in patients with stable chronic airways obstruction. Lancet. 1979;1(8111):294-7. [pmid: 84947].
Bentur L, Beck R, Berkowitz D, et al. Adenosine bronchial provocation with computerized wheeze detection in young infants with prolonged cough: correlation with long-term follow-up. Chest. 2004;126(4):1060-5. [pmid: 15486364].
Berninger A, Webber MP, Weakley J, et al. Quality of life in relation to upper and lower respiratory conditions among retired 9/11-exposed firefighters with pulmonary disability. Qual Life Res. 2010;19(10):1467-76. [pmid: 20680691].
Beydon N, M'Buila C, Bados A, et al. Interrupter resistance short-term repeatability and bronchodilator response in preschool children. Respir Med. 2007;101(12):2482-7. [pmid: 17720469].
Beydon N, Trang-Pham H, Bernard A, et al. Measurements of resistance by the interrupter technique and of transcutaneous partial pressure of oxygen in young children during methacholine challenge. Pediatr Pulmonol. 2001;31(3):238-46. [pmid: 11276137].
Binder RE, Mitchell CA. Use of the productive cough test to confirm presence of respiratory symptoms in school-age children. Am Rev Respir Dis. 1975;112(3):461-3. [pmid: 1163898].
Bingol Boz A, Aydn F, Celmeli F, et al. Does gastroesophageal reflux scintigraphy correlate with clinical findings in children with chronic cough?. Nucl Med Commun. 2009;30(10):802-6. [pmid: 19654561].
Blondeau K, Mertens V, Dupont L, et al. The relationship between gastroesophageal reflux and cough in children with chronic unexplained cough using combined impedance-pH-manometry recordings. Pediatr Pulmonol. 2010. [pmid: 20967945].
Bogte A, Bredenoord AJ, Smout AJ. Diagnostic yield of oesophageal pH monitoring in patients with chronic unexplained cough. Scand J Gastroenterol. 2008;43(1):13-9. [pmid: 18938747].
Borrelli O, Marabotto C, Mancini V, et al. Role of gastroesophageal reflux in children with unexplained chronic cough. Journal of Pediatric Gastroenterology and Nutrition. 2011;53(3):287-292. [pmid: 21865976].
Boulet LP, Laviolette M, Turcotte H, et al. Bronchial subepithelial fibrosis correlates with airway responsiveness to methacholine. Chest. 1997;112(1):45-52. [pmid: 9228356].
Boulet LP, Milot J, Boutet M, et al. Airway inflammation in nonasthmatic subjects with chronic cough. Am J Respir Crit Care Med. 1994;149(2 Pt 1):482-9. [pmid: 8306050].
Braido F, Baiardini I, Balestracci S, et al. The relationship between asthma control and quality-of-life impairment due to chronic cough: a real-life study. Ann Allergy Asthma Immunol. 2008;101(4):370-4. [pmid: 18939724].
Brightling CE, Ward R, Goh KL, et al. Eosinophilic bronchitis is an important cause of chronic cough. Am J Respir Crit Care Med. 1999;160(2):406-10. [pmid: 10430705].
Brightling CE, Ward R, Wardlaw AJ, et al. Airway inflammation, airway responsiveness and cough before and after inhaled budesonide in patients with eosinophilic bronchitis. Eur Respir J. 2000;15(4):682-6. [pmid: 10780759].
Brunekreef B, Groot B, Rijcken B, et al. Reproducibility of childhood respiratory symptom questions. Eur Respir J. 1992;5(8):930-5. [pmid: 1426200].
Bucca CB, Bugiani M, Culla B, et al. Chronic cough and irritable larynx. J Allergy Clin Immunol. 2011;127(2):412-9. [pmid: 21167571].
Bucknall CE, Neilly JB, Carter R, et al. Bronchial hyperreactivity in patients who cough after receiving angiotensin converting enzyme inhibitors. Br Med J (Clin Res Ed). 1988;296(6615):86-8. [pmid: 2827838].
Caporalini R, Giosue GL. Neltenexine in lung diseases: An open, randomised, controlled study versus N-acetylcysteine comparison. Minerva Pneumologica. 2001;40(2):57-62.
Carney IK, Gibson PG, Murree-Allen K, et al. A systematic evaluation of mechanisms in chronic cough. Am J Respir Crit Care Med. 1997;156(1):211-6. [pmid: 9230750].
Ceyhan BB, Karakurt S. Effect of oxolamine on cough sensitivity in COPD patients. Respir Med. 2002;96(1):61-3. [pmid: 11863211].
Chan KK, Ing AJ, Laks L, et al. Chronic cough in patients with sleep-disordered breathing. Eur Respir J. 2010;35(2):368-72. [pmid: 20123846].
Chang AB, Gibson PG, Willis C, et al. Do sex and atopy influence cough outcome measurements in children?. Chest. 2011;140(2):324-30. [pmid: 21393395].
Chang AB, Phelan PD, Robertson CF, et al. Frequency and perception of cough severity. J Paediatr Child Health. 2001;37(2):142-5. [pmid: 11328468].
Chang AB, Phelan PD, Sawyer SM, et al. Cough sensitivity in children with asthma, recurrent cough, and cystic fibrosis. Arch Dis Child. 1997;77(4):331-4. [pmid: 9389238].
Chang AB, Phelan PD, Sawyer SM, et al. Airway hyperresponsiveness and cough-receptor sensitivity in children with recurrent cough. Am J Respir Crit Care Med. 1997;155(6):1935-9. [pmid: 9196099].
Chatkin JM, Ansarin K, Silkoff PE, et al. Exhaled nitric oxide as a noninvasive assessment of chronic cough. Am J Respir Crit Care Med. 1999;159(6):1810-3. [pmid: 10351923].
Chausow AM, Banner AS. Comparison of the tussive effects of histamine and methacholine in humans. J Appl Physiol. 1983;55(2):541-6. [pmid: 6352579].
Cho YS, Park SY, Lee CK, et al. Enhanced cough response to hyperpnea with cold air challenge in chronic cough patients showing increased cough sensitivity to inhaled capsaicin. Allergy. 2003;58(6):486-91. [pmid: 12757448].
Choi WA, Park JH, Kim DH, et al. Cough assistance device for patients with glottis dysfunction and/or tracheostomy. J Rehabil Med. 2012;44(4):351-5. [pmid: 22453774].
Choudry NB, Fuller RW. Sensitivity of the cough reflex in patients with chronic cough. Eur Respir J. 1992;5(3):296-300. [pmid: 1572441].
Christensen EF, Nedergaard T, Dahl R. Long-term treatment of chronic bronchitis with positive expiratory pressure mask and chest physiotherapy. Chest. 1990;97(3):645-50. [pmid: 2106412].
Cloutier MM, Loughlin GM. Chronic cough in children: a manifestation of airway hyperreactivity. Pediatrics. 1981;67(1):6-12. [pmid: 7243436].
Corsico AG, Villani S, Zoia MC, et al. Chronic productive cough in young adults is very often due to chronic rhino-sinusitis. Monaldi Arch Chest Dis. 2007;67(2):90-4. [pmid: 17695692].
Cuijpers CE, Wesseling GJ, Swaen GM, et al. Asthma-related symptoms and lung function in primary school children. J Asthma. 1994;31(4):301-12. [pmid: 8040154].
Dani VS, Mogre SS, Saoji R. Evaluation of chronic cough in children: clinical and diagnostic spectrum and outcome of specific therapy. Indian Pediatr. 2002;39(1):63-9. [pmid: 11805355].
David D, Jallad N, Germino FW, et al. A Comparison of the Cough Profile of Fosinopril and Enalapril in Hypertensive Patients with a History of ACE Inhibitor-Associated Cough. Am J Ther. 1995;2(10):806-813. [pmid: 11854791].
de Benedictis FM, Canny GJ, Levison H. Methacholine inhalational challenge in the evaluation of chronic cough in children. J Asthma. 1986;23(6):303-8. [pmid: 3546254].
De Diego A, Martinez E, Perpina M, et al. Airway inflammation and cough sensitivity in cough-variant asthma. Allergy. 2005;60(11):1407-11. [pmid: 16197473].
Deilami GD, Khandashpour M, Paknejad O, et al. Evaluation of methacholine challenge test results in chronic cough patients referring to clinic of pulmonary disease. Acta Medica Iranica. 2009;47(3):175-179.
Demers RY, Fischetti LR, Neale AV. Incongruence between self-reported symptoms and objective evidence of respiratory disease among construction workers. Soc Sci Med. 1990;30(7):805-10. [pmid: 2315748].
DeVault K, Achem S, Lee A, et al. Cough and GRRD: Prevalence, association and effect of gender in uninvestigated and untreated patients over age 65. American Journal of Gastroenterology. 2011;106:S29-S30.
Dohna-Schwake C, Ragette R, Teschler H, et al. IPPB-assisted coughing in neuromuscular disorders. Pediatr Pulmonol. 2006;41(6):551-7. [pmid: 16617451].
Edwards GF, Lewis HE, Stafford D. The effect of pholcodine with and without an antihistamine on cough and expectoration. Br J Dis Chest. 1977;71(4):245-52. [pmid: 22340].
Elkins MR, Robinson M, Rose BR, et al. A controlled trial of long-term inhaled hypertonic saline in patients with cystic fibrosis. N Engl J Med. 2006;354(3):229-40. [pmid: 16421364].
Field GB. The application of a quantitative estimate of cough frequency to epidemiological surveys. Int J Epidemiol. 1974;3(2):135-43. [pmid: 4854653].
Fifoot S, Wilson C, MacDonald J, et al. Respiratory exacerbations in children with cystic fibrosis: physiotherapy treatment outcomes. Physiother Theory Pract. 2005;21(2):103-11. [pmid: 16392463].
Formanek W, Inci D, Lauener RP, et al. Elevated nitrite in breath condensates of children with respiratory disease. Eur Respir J. 2002;19(3):487-91. [pmid: 11936527].
French CT, Fletcher KE, Irwin RS. A comparison of gender differences in health-related quality of life in acute and chronic coughers. Chest. 2005;127(6):1991-8. [pmid: 15947311].
French CT, Fletcher KE, Irwin RS. Gender differences in health-related quality of life in patients complaining of chronic cough. Chest. 2004;125(2):482-8. [pmid: 14769728].
Frigerio G, Lodola E, Sperotti L. The antitussive activity of diviminol (Z.424). Curr Ther Res Clin Exp. 1970;12(8):516-9. [pmid: 4988838].
Fujimoto K, Yamaguchi S, Urushibata K, et al. Sputum eosinophilia and bronchial responsiveness in patients with chronic non-productive cough responsive to anti-asthma therapy. Respirology. 2003;8(2):168-74. [pmid: 12753531].
Fujimura M, Abo M, Ogawa H, et al. Importance of atopic cough, cough variant asthma and sinobronchial syndrome as causes of chronic cough in the Hokuriku area of Japan. Respirology. 2005;10(2):201-7. [pmid: 15823186].
Fujimura M, Kamio Y, Hashimoto T, et al. Cough receptor sensitivity and bronchial responsiveness in patients with only chronic nonproductive cough: in view of effect of bronchodilator therapy. J Asthma. 1994;31(6):463-72. [pmid: 7961323].
Fujimura M, Ohkura N, Abo M, et al. Exhaled nitric oxide levels in patients with atopic cough and cough variant asthma. Respirology. 2008;13(3):359-64. [pmid: 18399857].
Fujimura M, Sakamoto S, Matsuda T. Bronchodilator-resistive cough in atopic patients: bronchial reversibility and hyperresponsiveness. Intern Med. 1992;31(4):447-52. [pmid: 1352997].
Fujimura M, Songur N, Kamio Y, et al. Detection of eosinophils in hypertonic saline-induced sputum in patients with chronic nonproductive cough. J Asthma. 1997;34(2):119-26. [pmid: 9088298].
Gharagozlou M, Kompani F, Movahedi M. Comparison between peak expiratory flow rate and forced expiratory volume in one second in the evaluation of children suspected to have asthma. Iran J Allergy Asthma Immunol. 2004;3(1):21-4. [pmid: 17301387].
Ghezzi M, Guida E, Ullmann N, et al. Weakly acidic gastroesophageal refulxes are frequently triggers in young children with chronic cough. Pediatric Pulmonology. 2012. [epub ahead of print]. [pmid: 22553136].
Gibson PG, Simpson JL, Chalmers AC, et al. Airway eosinophilia is associated with wheeze but is uncommon in children with persistent cough and frequent chest colds. Am J Respir Crit Care Med. 2001;164(6):977-81. [pmid: 11587982].
Gibson PG, Zlatic K, Scott J, et al. Chronic cough resembles asthma with IL-5 and granulocyte-macrophage colony-stimulating factor gene expression in bronchoalveolar cells. J Allergy Clin Immunol. 1998;101(3):320-6. [pmid: 9525446].
Goss CH, Edwards TC, Ramsey BW, et al. Patient-reported respiratory symptoms in cystic fibrosis. J Cyst Fibros. 2009;8(4):245-52. [pmid: 19481983].
Gross V, Reinke C, Dette F, et al. Mobile nocturnal long-term monitoring of wheezing and cough. Biomed Tech (Berl). 2007;52(1):73-6. [pmid: 17313338].
Gulsvik A, Refvem OK. A scoring system on respiratory symptoms. Eur Respir J. 1988;1(5):428-32. [pmid: 3169213].
Hadjikoutis S, Eccles R, Wiles CM. Coughing and choking in motor neuron disease. J Neurol Neurosurg Psychiatry. 2000;68(5):601-4. [pmid: 10766890].
Hahn PY, Morgenthaler TY, Lim KG. Use of exhaled nitric oxide in predicting response to inhaled corticosteroids for chronic cough. Mayo Clin Proc. 2007;82(11):1350-5. [pmid: 17976354].
Hammond CS. Evaluating cough: The role of dysphagia and aspiration. Journal of Respiratory Diseases. 2008;29(7):263-265.
Harnden A, Grant C, Harrison T, et al. Whooping cough in school age children with persistent cough: prospective cohort study in primary care. BMJ. 2006;333(7560):174-7. [pmid: 16829538].
Hensley MJ, Chalmers A, Clover K, et al. Symptoms of asthma: comparison of a parent-completed retrospective questionnaire with a prospective daily symptom diary. Pediatr Pulmonol. 2003;36(6):509-13. [pmid: 14618643].
Higuchi O, Adachi Y, Itazawa T, et al. Relationship between rhinitis and nocturnal cough in school children. Pediatric Allergy and Immunology. 2012;23(6):562-6. [pmid: 22554384].
Hunt J, Yu Y, Burns J, et al. Identification of acid reflux cough using serial assays of exhaled breath condensate pH. Cough. 2006;2:3. [pmid: 16608520].
Ing AJ, Ngu MC, Breslin AB. Chronic persistent cough and clearance of esophageal acid. Chest. 1992;102(6):1668-71. [pmid: 1446469].
Ing AJ, Ngu MC, Breslin AB. Chronic persistent cough and gastro-oesophageal reflux. Thorax. 1991;46(7):479-83. [pmid: 1877035].
Irwin RS, Curley FJ, French CL. Chronic cough. The spectrum and frequency of causes, key components of the diagnostic evaluation, and outcome of specific therapy. Am Rev Respir Dis. 1990;141(3):640-7. [pmid: 2178528].
Irwin RS, French CT, Smyrnios NA, et al. Interpretation of positive results of a methacholine inhalation challenge and 1 week of inhaled bronchodilator use in diagnosing and treating cough-variant asthma. Arch Intern Med. 1997;157(17):1981-7. [pmid: 9308510].
Jain NB, Sullivan M, Kazis LE, et al. Factors associated with health-related quality of life in chronic spinal cord injury. Am J Phys Med Rehabil. 2007;86(5):387-96. [pmid: 17449983].
Jakeways N, McKeever T, Lewis SA, et al. Relationship between FEV1 reduction and respiratory symptoms in the general population. Eur Respir J. 2003;21(4):658-63. [pmid: 12762353].
Jarad NA, Sequeiros IM. A novel respiratory symptom scoring system for CF pulmonary exacerbations. QJM. 2012;105(2):137-43. [pmid: 21908385].
Jayaram S, Desai A. Efficacy and safety of Ascoril expectorant and other cough formula in the treatment of cough management in paediatric and adult patients--a randomised double-blind comparative trial. J Indian Med Assoc. 2000;98(2):68-70. [pmid: 11016157].
Jesenak M, Babusikova E, Petrikova M, et al. Cough reflex sensitivity in various phenotypes of childhood asthma. J Physiol Pharmacol. Suppl 5. 2009;60:61-5. [pmid: 20134041].
Jones PD, Hankin R, Simpson J, et al. The tolerability, safety, and success of sputum induction and combined hypertonic saline challenge in children. Am J Respir Crit Care Med. 2001;164(7):1146-9. [pmid: 11673200].
Jones PW, Chen WH, Wilcox TK, et al. Characterizing and quantifying the symptomatic features of COPD exacerbations. Chest. 2011;139(6):1388-94. [pmid: 21071529].
Kang H, Koh YY, Yoo Y, et al. Maximal airway response to methacholine in cough-variant asthma: comparison with classic asthma and its relationship to peak expiratory flow variability. Chest. 2005;128(6):3881-7. [pmid: 16354858].
Kapaskelis AM, Vouloumanou EK, Rafailidis PI, et al. High prevalence of antibody titers against Bordetella pertussis in an adult population with prolonged cough. Respir Med. 2008;102(11):1586-91. [pmid: 18684605].
Kapur N, Masters IB, Morris PS, et al. Defining pulmonary exacerbation in children with non-cystic fibrosis bronchiectasis. Pediatr Pulmonol. 2011. [pmid: 21830316].
Kapur N, Masters IB, Newcombe P, et al. The burden of disease in pediatric non-cystic fibrosis bronchiectasis. Chest. 2011. [pmid: 21885727].
Kastelik JA, Thompson RH, Aziz I, et al. Sex-related differences in cough reflex sensitivity in patients with chronic cough. Am J Respir Crit Care Med. 2002;166(7):961-4. [pmid: 12359654].
Kerem E, Wilschanski M, Miller NL, et al. Ambulatory quantitative waking and sleeping cough assessment in patients with cystic fibrosis. J Cyst Fibros. 2011;10(3):193-200. [pmid: 21459051].
Knocikova J, Korpas J, Vrabec M, et al. Wavelet analysis of voluntary cough sound in patients with respiratory diseases. J Physiol Pharmacol. Suppl 6. 2008;59:331-40. [pmid: 19218657].
Korpas J, Vrabec M, Sadlonova J, et al. Single, double and multi cough sound differentiation. Acta Physiologica Hungarica. 2005;92(3-4):203-209.
Koskela HD, Purokivi MK, Nieminen RM, et al. Asthmatic cough and airway oxidative stress. Respir Physiol Neurobiol. 2012;181(3):346-50. [pmid: 22546340].
Lim KG, Rank MA, Kita H, et al. Neuropeptide levels in nasal secretions from patients with and without chronic cough. Annals of Allergy, Asthma and Immunology. 2011;107(4):360-363.
Liu B, Yu L, Qiu ZH, et al. The diagnostic value of multichannel intraluminal esophageal impedance andph monitoring for gastroesophageal reflux-related chronic cough. Respirology. 2011;16:1.
Marchant JM, Masters IB, Taylor SM, et al. Utility of signs and symptoms of chronic cough in predicting specific cause in children. Thorax. 2006;61(8):694-8. [pmid: 16670171].
Marchant JM, Masters IB, Taylor SM, et al. Evaluation and outcome of young children with chronic cough. Chest. 2006;129(5):1132-41. [pmid: 16685002].
Matsumoto H, Tabuena RP, Niimi A, et al. Cough triggers and their pathophysiology in patients with prolonged or chronic cough. Allergol Int. 2012;61(1):123-32. [pmid: 22377525].
Moretti M, Lopez-Vidriero MT, Pavia D, et al. Relationship between bronchial reversibility and tracheobronchial clearance in patients with chronic bronchitis. Thorax. 1997;52(2):176-80. [pmid: 9059481].
Morice AH, Faruqi S, Wright CE, et al. Cough hypersensitivity syndrome: a distinct clinical entity. Lung. 2011;189(1):73-9. [pmid: 21240613].
Morrison RJ, Schindler JS. Evaluation and treatment of the patient with chronic cough referred to the otolaryngologist. Laryngoscope. 2011;121(Suppl 5):S256.
Murata A, Taniguchi Y, Hashimoto Y, et al. Discrimination of productive and non-productive cough by sound analysis. Intern Med. 1998;37(9):732-5. [pmid: 9804079].
Mutalithas K, Watkin G, Willig B, et al. Improvement in health status following bronchopulmonary hygiene physical therapy in patients with bronchiectasis. Respir Med. 2008;102(8):1140-4. [pmid: 18585027].
Nicolis FB, Pasquariello G. Controlled clinical trials of antitussive agents: an experimental evaluation of different methods. J Pharmacol Exp Ther. 1962;136:183-9. [pmid: 14479574].
Nogami H, Odajima H, Shoji S, et al. Capsaicin provocation test as a diagnostic method for determining multiple chemical sensitivity. Allergology International. 2004;53(2):153-157.
O'Connell F, Thomas VE, Studham JM, et al. Capsaicin cough sensitivity increases during upper respiratory infection. Respir Med. 1996;90(5):279-86. [pmid: 9499812].
Olivieri D, Ciaccia A, Marangio E, et al. Role of bromhexine in exacerbations of bronchiectasis. Double-blind randomized multicenter study versus placebo. Respiration. 1991;58(3-4):117-21. [pmid: 1745841].
Olivieri D, Del Donno M, Casalini A, et al. Activity of erdosteine on mucociliary transport in patients affected by chronic bronchitis. Respiration. 1991;58(2):91-4. [pmid: 1862257].
Olseni L, Stentoft J, Hornblad Y. Mucus clearance in patients with chronic non-productive cough. Applied Cardiopulmonary Pathophysiology. 1996;6(2):139-144.
Paneroni M, Clini E, Simonelli C, et al. Safety and efficacy of short-term intrapulmonary percussive ventilation in patients with bronchiectasis. Respir Care. 2011;56(7):984-8. [pmid: 21352670].
Parameswaran K, Allen CJ, Kamada D, et al. Sputum cell counts and exhaled nitric oxide in patients with gastroesophageal reflux, and cough or asthma. Can Respir J. 2001;8(4):239-44. [pmid: 11521139].
Park HW, Kim SH, Chang YS, et al. Complementary roles of capsaicin cough sensitivity test and induced sputum test to methacholine bronchial provocation test in predicting response to inhaled corticosteroids in patients with chronic nonproductive cough. Ann Allergy Asthma Immunol. 2007;98(6):533-9. [pmid: 17601265].
Paterson WG, Murat BW. Combined ambulatory esophageal manometry and dual-probe pH-metry in evaluation of patients with chronic unexplained cough. Dig Dis Sci. 1994;39(5):1117-25. [pmid: 8174426].
Patria MF, Fusi M, Pietrogrande MC, et al. Serial high-resolution computed tomography (HRCT) in children with chronic productive cough and bronchiectasis unrelated to cystic fibrosis: Correlations with clinical evaluation. Italian Journal of Pediatrics. 2006;32(2):112-117.
Pavesi L, Subburaj S, Porter-Shaw K. Application and validation of a computerized cough acquisition system for objective monitoring of acute cough: a meta-analysis. Chest. 2001;120(4):1121-8. [pmid: 11591548].
Pavia D, Agnew JE, Glassman JM, et al. Effects of iodopropylidene glycerol on tracheobronchial clearance in stable, chronic bronchitic patients. Eur J Respir Dis. 1985;67(3):177-84. [pmid: 3908131].
Penman RW, O'Neill RP, Begley L. The progress of chronic airway obstruction in relation to measurements of airway resistance and lung elastic recoil. Am Rev Respir Dis. 1970;101(4):536-44. [pmid: 5439875].
Petsios KT, Priftis KN, Tsoumakas C, et al. Cough affects quality of life in asthmatic children aged 8-14 more than other asthma symptoms. Allergol Immunopathol (Madr). 2009;37(2):80-8. [pmid: 19445864].
Petsky HL, Acworth JP, Clark R, et al. Asthma and protracted bronchitis: who fares better during an acute respiratory infection?. J Paediatr Child Health. 2009;45(1-2):42-7. [pmid: 19208065].
Petsonk EL, Wang ML. Interpreting screening questionnaires: specific respiratory symptoms and their relationship to objective test results. J Occup Environ Med. 2010;52(12):1225-9. [pmid: 21124238].
Pettit RS, Johnson CE. Airway-Rehydrating agents for the treatment of cystic fibrosis: Past, present, and future. Annals of Pharmacotherapy. 2011;45(1):49-59. [pmid: 21156814].
Piirila P, Sovijarvi AR. Differences in acoustic and dynamic characteristics of spontaneous cough in pulmonary diseases. Chest. 1989;96(1):46-53. [pmid: 2736992].
Piquette CA, Clarkson L, Okamoto K, et al. Respiratory-related quality of life: relation to pulmonary function, functional exercise capacity, and sputum biophysical properties. J Aerosol Med. 2000;13(3):263-72. [pmid: 11066029].
Plante C, Jacques L, Chevalier S, et al. Comparability of internet and telephone data in a survey on the respiratory health of children. Canadian Respiratory Journal. 2012;19(1):13-8. [pmid: 22332126].
Poe RH, Harder RV, Israel RH, et al. Chronic persistent cough. Experience in diagnosis and outcome using an anatomic diagnostic protocol. Chest. 1989;95(4):723-8. [pmid: 2924600].
Power JT, Stewart IC, Connaughton JJ, et al. Nocturnal cough in patients with chronic bronchitis and emphysema. Am Rev Respir Dis. 1984;130(6):999-1001. [pmid: 6508020].
Prieto L, Ferrer A, Ponce S, et al. Exhaled nitric oxide measurement is not useful for predicting the response to inhaled corticosteroids in subjects with chronic cough. Chest. 2009;136(3):816-22. [pmid: 19411296].
Prudon B, Birring SS, Vara DD, et al. Cough and glottic-stop reflex sensitivity in health and disease. Chest. 2005;127(2):550-7. [pmid: 15705995].
Puolijoki H, Nieminen MM, Moilanen E, et al. Bradykinin: A putative mediator of enalapril-induced cough. Current Therapeutic Research - Clinical and Experimental. 1992;51(6):844-847.
Purokivi M, Koskela H, Koistinen T, et al. Assessment of inhaled corticosteroid treatment response in asthma using hypertonic histamine challenge-induced cough. Clin Respir J. 2010;4(2):67-73. [pmid: 20565479].
Qiu Z, Yu L, Xu S, et al. Cough reflex sensitivity and airway inflammation in patients with chronic cough due to non-acid gastro-oesophageal reflux. Respirology. 2011;16(4):645-52. [pmid: 21342332].
Ravez P, Richez M, Godart G, et al. Effect of intermittent high-frequency intrapulmonary percussive breathing on mucus transport. Eur J Respir Dis Suppl. 1986;146:285-9. [pmid: 3536553].
Redding GJ, Kishioka C, Martinez P, et al. Physical and transport properties of sputum from children with idiopathic bronchiectasis. Chest. 2008;134(6):1129-34. [pmid: 18753467].
Rehman A, Waraich MM, Irfanullah. Algorithm for the diagnosis of chronic cough in children 6 to 59-months. Pakistan Paediatric Journal. 2009;33(1):30-38.
Ren CL, Rosenfeld M, Mayer OH, et al. Analysis of the associations between lung function and clinical features in preschool children with Cystic Fibrosis. Pediatric Pulmonology. 2012;47(6):574-81. [pmid: 22081584].
Repsher LH. Treatment of stable chronic bronchitis with iodinated glycerol: a double-blind, placebo-controlled trial. J Clin Pharmacol. 1993;33(9):856-60. [pmid: 8227484].
Ribeiro M, De Castro Pereira CA, Nery LE, et al. A prospective longitudinal study of clinical characteristics, laboratory findings, diagnostic spectrum and outcomes of specific therapy in adult patients with chronic cough in a general respiratory clinic. Int J Clin Pract. 2006;60(7):799-805. [pmid: 16858753].
Ribeiro M, Pereira CA, Nery LE, et al. Methacholine vs adenosine on intra and extrathoracic airway hyperresponsiveness in patients with cough variant asthma. Allergy. 2008;63(5):527-32. [pmid: 18394126].
Rietveld S, Rijssenbeek-Nouwens LH. Diagnostics of spontaneous cough in childhood asthma: results of continuous tracheal sound recording in the homes of children. Chest. 1998;113(1):50-4. [pmid: 9440567].
Rietveld S, Rijssenbeek-Nouwens LH, Prins PJ. Cough as the ambiguous indicator of airway obstruction in asthma. J Asthma. 1999;36(2):177-86. [pmid: 10227269].
Rietveld S, Van Beest I, Everaerd W. Psychological confounds in medical research: the example of excessive cough in asthma. Behav Res Ther. 2000;38(8):791-800. [pmid: 10937427].
Rimoldi R, Bonollo L, Martini A, et al. Controlled clinical study of a cough-relief treatment (cardiazol-paracodina) in pneumopathic patients. Current Therapeutic Research - Clinical and Experimental. 1990;48(6):1053-65.
Rimsza ME, Newberry S. Unexpected infant deaths associated with use of cough and cold medications. Pediatrics. 2008;122(2):e318-22. [pmid: 18676517].
Riordan MF, Beardsmore CS, Brooke AM, et al. Relationship between respiratory symptoms and cough receptor sensitivity. Arch Dis Child. 1994;70(4):299-304. [pmid: 8185363].
Rosenfeld M, Ratjen F, Brumback L, et al. Inhaled hypertonic saline in infants and children younger than 6 years with Cyctic Fibrosis: the ISIS Randomized Controlled Trial Inhaled Hypertonic Saline in Children With CF. JAMA. 2012;307(21):2269-77. [pmid: 22610452].
Rubin BK. Therapeutic aerosols and airway secretions. J Aerosol Med. 1996;9(1):123-30. [pmid: 10160202].
Ryan NM, Vertigan AE, Ferguson J, et al. Clinical and physiological features of postinfectious chronic cough associated with H1N1 infection. Respiratory Medicine. 2012;106(1):138-44. [pmid: 22056406].
Ryan NM, Gibson PG. Characterization of laryngeal dysfunction in chronic persistent cough. Laryngoscope. 2009;119(4):640-5. [pmid: 19205007].
Sadlonova J, Salat D, Salatova V. Tussiphonogram in probands with chronic obstructive bronchitis. Acta Physiol Hung. 1987;70(2-3):171-5. [pmid: 3434296].
Saito J, Harris WT, Gelfond J, et al. Physiologic, bronchoscopic, and bronchoalveolar lavage fluid findings in young children with recurrent wheeze and cough. Pediatr Pulmonol. 2006;41(8):709-19. [pmid: 16779841].
Salat D, Korpas J, Salatova V, et al. The tussiphonogram during asthmatic attack. Acta Physiol Hung. 1987;70(2-3):223-5. [pmid: 3434301].
Salmi T, Sovijarvi AR, Brander P, et al. Long-term recording and automatic analysis of cough using filtered acoustic signals and movements on static charge sensitive bed. Chest. 1988;94(5):970-5. [pmid: 3180900].
Sano T, Ueda H, Bando H. A preliminary study of PEFR monitoring in patients with chronic cough. Lung. 2004;182(5):285-95. [pmid: 15742241].
Sato S, Saito J, Sato Y, et al. Clinical usefulness of fractional exhaled nitric oxide for diagnosing prolonged cough. Respir Med. 2008;102(10):1452-9. [pmid: 18614345].
Schokker S, Kooi EM, de Vries TW, et al. Inhaled corticosteroids for recurrent respiratory symptoms in preschool children in general practice: randomized controlled trial. Pulm Pharmacol Ther. 2008;21(1):88-97. [pmid: 17350868].
Sen RP, Walsh TE. Fiberoptic bronchoscopy for refractory cough. Chest. 1991;99(1):33-5. [pmid: 1984981].
Serembe M, Barbetti M. Clinical trials on a new antitussive agent. 2-morpholinoethylic ester of a-phenoxyisobutyric acid (morphethylbutyne). Farmaco Prat. 1969;24(11):700-6. [pmid: 4902988].
Sergysels R, Art G. A double-masked, placebo-controlled polysomnographic study of the antitussive effects of helicidine. Current Therapeutic Research - Clinical and Experimental. 2001;62(1):35-47.
Sevelius H, Colmore JP. Antitussive effect of ethyl dibunate in patients with chronic cough. Clin Pharmacol Ther. 1967;8(3):381-4. [pmid: 5338382].
Sevelius H, Colmore JP. Objective assessment of antitussive agents in patients with chronic cough. J New Drugs. 1966;6(4):216-23. [pmid: 5338653].
Shin SH, Hashimoto T, Hatano S. Automatic detection system for cough sounds as a symptom of abnormal health condition. IEEE Trans Inf Technol Biomed. 2009;13(4):486-93. [pmid: 19273017].
Sifrim D, Dupont L, Blondeau K, et al. Weakly acidic reflux in patients with chronic unexplained cough during 24 hour pressure, pH, and impedance monitoring. Gut. 2005;54(4):449-54. [pmid: 15753524].
Smyrnios NA, Irwin RS, Curley FJ. Chronic cough with a history of excessive sputum production. The spectrum and frequency of causes, key components of the diagnostic evaluation, and outcome of specific therapy. Chest. 1995;108(4):991-7. [pmid: 7555175].
Smyrnios NA, Irwin RS, Curley FJ, et al. From a prospective study of chronic cough: diagnostic and therapeutic aspects in older adults. Arch Intern Med. 1998;158(11):1222-8. [pmid: 9625401].
Snijders D, Cattarozzi A, Panizzolo C, et al. Investigation of children with chronic nonspecific cough: any clinical benefit of bronchoscopy and bronchoalveolar lavage?. Allergy Asthma Proc. 2007;28(4):462-7. [pmid: 17883915].
Solopov VN, Lunichkina IV. Expectoration disturbances and bronchial obstruction. Respiration. 1991;58(5-6):287-93. [pmid: 1792419].
Spiropoulos K, Stevens J, Eigen H, et al. Specificity and sensitivity of methacholine challenge test in children with normal and hyperreactive airways. Acta Paediatr Scand. 1986;75(5):737-43. [pmid: 3564942].
Springer C, Godfrey S, Vilozni D, et al. Comparison of respiratory inductance plethysmography with thoracoabdominal compression in bronchial challenges in infants and young children. Am J Respir Crit Care Med. 1996;154(3 Pt 1):665-9. [pmid: 8810603].
Stec SM, Grabczak EM, Bielicki P, et al. Diagnosis and management of premature ventricular complexes-associated chronic cough. Chest. 2009;135(6):1535-41. [pmid: 19318662].
Strippoli MP, Silverman M, Michel G, et al. A parent-completed respiratory questionnaire for 1-year-old children: repeatability. Arch Dis Child. 2007;92(10):861-5. [pmid: 17502330].
Su CL, Chang CC, Lin YK, et al. Randomized Crossover Study for Lung Expansion Therapy Using Negative Pressure and Positive Pressure in Bronchiectasis. Journal of Experimental and Clinical Medicine. 2012.
Sugimura T, Ozaki Y, Tananari Y, et al. Auscultation using a pinwheel in young children presenting with cough. Pediatric Asthma, Allergy and Immunology. 2009;22(3):111-113.
Ternesten-Hasseus E, Johansson K, Lowhagen O, et al. Inhalation method determines outcome of capsaicin inhalation in patients with chronic cough due to sensory hyperreactivity. Pulm Pharmacol Ther. 2006;19(3):172-8. [pmid: 15990345].
Ternesten-Hasseus E, Larsson C, Bende M, et al. Capsaicin provocation using two different inhalation devices. Respir Med. 2008;102(12):1784-90. [pmid: 18703328].
Thiadens HA, de Bock GH, Dekker FW, et al. Identifying asthma and chronic obstructive pulmonary disease in patients with persistent cough presenting to general practitioners: descriptive study. BMJ. 1998;316(7140):1286-90. [pmid: 9554899].
Thiadens HA, De Bock GH, Van Houwelingen JC, et al. Can peak expiratory flow measurements reliably identify the presence of airway obstruction and bronchodilator response as assessed by FEV(1) in primary care patients presenting with a persistent cough?. Thorax. 1999;54(12):1055-60. [pmid: 10567623].
Thomas J, Heurich AE, Shepherd DA, et al. A system for the clinical assessment of the antitussive activity of caramiphen. Curr Ther Res Clin Exp. 1974;16(10):1082-90. [pmid: 4215619].
Thompson KJ, Reeve J. A clinical trial of bromhexine. N Z Med J. 1972;76(483):73-6. [pmid: 4264310].
Thomson ML, Pavia D, Gregg I, et al. The effect of bromhexine on mucociliary clearance from the human lung in chronic bronchitis. Scand J Respir Dis Suppl. 1974;90:75-9. [pmid: 4533555].
Thomson ML, Pavia D, Jones CJ, et al. No demonstrable effect of S-carboxymethylcysteine on clearance of secretions from the human lung. Thorax. 1975;30(6):669-73. [pmid: 769242].
Todokoro M, Mochizuki H, Tokuyama K, et al. Childhood cough variant asthma and its relationship to classic asthma. Ann Allergy Asthma Immunol. 2003;90(6):652-9. [pmid: 12839325].
Turktas I, Dalgic N, Bostanci I, et al. Extrathoracic airway responsiveness in children with asthma-like symptoms, including chronic persistent cough. Pediatr Pulmonol. 2002;34(3):172-80. [pmid: 12203845].
Urkin J, Ishay Y, Bilenko N, et al. Night-time cough in children with acute wheezing and with upper respiratory tract infection. Prim Care Respir J. 2008;17(4):217-21. [pmid: 18633556].
Vaezi MF, Richter JE. Twenty-four-hour ambulatory esophageal pH monitoring in the diagnosis of acid reflux-related chronic cough. South Med J. 1997;90(3):305-11. [pmid: 9076302].
Valenti S, Marenco G. Italian multicenter study on the treatment of chronic obstructive lung disease with bromhexine. A double-blind placebo-controlled trial. Respiration. 1989;56(1-2):11-5. [pmid: 2690235].
Van Hirtum A, Berckmans D. Automated recognition of spontaneous versus voluntary cough. Med Eng Phys. 2002;24(7-8):541-5. [pmid: 12237051].
Vardar R, Sweis R, Anggiansah A, et al. Pharyngeal and oesophageal dysmotility and dysfunction in patients with chronic cough: Assessment by high-resolution manometry. Gut. 2011;60:A165.
Vas M, Kun A. A new antitussive (libexin) for geriatric use. Ther Hung. 1967;15(1):32-4. [pmid: 5343252].
Vertigan AE, Theodoros DG, Winkworth AL, et al. A comparison of two approaches to the treatment of chronic cough: perceptual, acoustic, and electroglottographic outcomes. J Voice. 2008;22(5):581-9. [pmid: 17485195].
Wang J, Sicherer SH. Coughing in pre-school children in general practice: When are RAST's for inhalation allergy indicated?. Pediatrics. 2005;116(2):559.
Wark PA, Gibson PG, Fakes K. Induced sputum eosinophils in the assessment of asthma and chronic cough. Respirology. 2000;5(1):51-7. [pmid: 10728732].
Wongtim S, Chareonlap P, Mogmued S. Methacholine inhalation challenge in patients with chronic cough induced by angiotensin-converting enzyme inhibitors. J Med Assoc Thai. 1996;79(3):166-70. [pmid: 8708498].
Wongtim S, Mogmeud S, Limthongkul S, et al. The role of the methacholine inhalation challenge in adult patients presenting with chronic cough. Asian Pac J Allergy Immunol. 1997;15(1):9-14. [pmid: 9251842].
Wongtim S, Mogmud S, Chareonlap P, et al. Standardization of methacholine inhalation challenge by a reservoir method. Asian Pac J Allergy Immunol. 1994;12(2):131-6. [pmid: 7612106].
Worrall GJ. One hundred coughs: family practice case series. Can Fam Physician. 2008;54(2):236-7. [pmid: 18272642].
Young EC, Brammer C, Owen E, et al. The effect of mindfulness meditation on cough reflex sensitivity. Thorax. 2009;64(11):993-8. [pmid: 19679578].
Yu L, Qiu ZH, Wei WL, et al. Discrepancy between presumptive and definite causes of chronic cough. Chinese Medical Journal. 2011;124(24):4138-43. [pmid: 22340375].
Zanasi A, De Bernardi M, Messina P, et al. Cough sedation: Effectiveness and safety of the association dextromethorphan-guaiafenesin. Acta Toxicologica et Therapeutica. 1993;14(3):153-162.
Zgherea D, Pagala S, Mendiratta M, et al. Bronchoscopic findings in children with chronic wet cough. Pediatrics. 2012;129(2):e364-9. [pmid: 22232311].

## No comparator

Bastian RW, Vaidya AM, Delsupehe KG. Sensory neuropathic cough: a common and treatable cause of chronic cough. Otolaryngol Head Neck Surg. 2006;135(1):17-21. [pmid: 16815176].
Bector NP, Puri AS. Solanum xanthocarpum (Kantakari) in chronic bronchitis, bronchial asthma and non-specific unproductive cough. (An experimental and clinical co-relation). J Assoc Physicians India. 1971;19(10):741-4. [pmid: 5132261].
Chong CF, Chen CC, Ma HP, et al. Comparison of lidocaine and bronchodilator inhalation treatments for cough suppression in patients with chronic obstructive pulmonary disease. Emerg Med J. 2005;22(6):429-32. [pmid: 15911951].
Freestone C, Eccles R, Morris S, et al. Assessment of the antitussive efficacy of codeine using cough sound pressure levels as a means of measuring cough. Pulm Pharmacol. 1996;9(5-6):365. [pmid: 9232676].
Homsi J, Walsh D, Nelson KA, et al. A phase II study of hydrocodone for cough in advanced cancer. Am J Hosp Palliat Care. 2002;19(1):49-56. [pmid: 12171425].
Howard P, Cayton RM, Brennan SR, et al. Lignocaine aerosol and persistent cough. Br J Dis Chest. 1977;71(1):19-24. [pmid: 831764].
Johansson EL, Ternesten-Hasseus E, Millqvist E. Down-regulation of cough sensitivity after eucapnic dry air provocation in chronic idiopathic cough. Pulm Pharmacol Ther. 2009;22(6):543-7. [pmid: 19646543].
Kamimura M, Mouri A, Takayama K, et al. Cough challenge tests involving mechanical stimulation of the cervical trachea in patients with cough as a leading symptom. Respirology. 2010;15(8):1244-51. [pmid: 20920133].
Kopriva F, Sobolova L, Szotkowska J, et al. Treatment of chronic cough in children with montelukast,a leukotriene receptor antagonist. J Asthma. 2004;41(7):715-20. [pmid: 15584630].
Kuzniar TJ, Morgenthaler TI, Afessa B, et al. Chronic cough from the patient's perspective. Mayo Clin Proc. 2007;82(1):56-60. [pmid: 17285786].
Leconte S, Ferrant D, Dory V, et al. Validated methods of cough assessment: a systematic review of the literature. Respiration. 2011;81(2):161-74. [pmid: 21079381].
Levine BM. Systematic evaluation and treatment of chronic cough in a community setting. Allergy Asthma Proc. 2008;29(3):336-42. [pmid: 18534091].
Lokshin B, Lindgren S, Weinberger M, et al. Outcome of habit cough in children treated with a brief session of suggestion therapy. Ann Allergy. 1991;67(6):579-82. [pmid: 1750719].
Macedo P, Saleh H, Torrego A, et al. Postnasal drip and chronic cough: An open interventional study. Respir Med. 2009;103(11):1700-5. [pmid: 19481918].
Murry T, Branski RC, Yu K, et al. Laryngeal sensory deficits in patients with chronic cough and paradoxical vocal fold movement disorder. Laryngoscope. 2010;120(8):1576-81. [pmid: 20564660].
Murry T, Tabaee A, Owczarzak V, et al. Respiratory retraining therapy and management of laryngopharyngeal reflux in the treatment of patients with cough and paradoxical vocal fold movement disorder. Ann Otol Rhinol Laryngol. 2006;115(10):754-8. [pmid: 17076097].
Nunes CP, De Oliveira PC, De Oliveira JM, et al. Quality-of-life assessment and clinical-laboratory response to use of the combination of menthol, guaiacol, terpineol, eucalyptol, gomenol, and camphor in patients presenting persistent cough. Revista Brasileira de Medicina. 2010;67(4):104-109.
Ours TM, Kavuru MS, Schilz RJ, et al. A prospective evaluation of esophageal testing and a double-blind, randomized study of omeprazole in a diagnostic and therapeutic algorithm for chronic cough. Am J Gastroenterol. 1999;94(11):3131-8. [pmid: 10566703].
Patel AS, Watkin G, Willig B, et al. Improvement in health status following cough-suppression physiotherapy for patients with chronic cough. Chron Respir Dis. 2011. [pmid: 21990570].
Pratter MR, Bartter T, Lotano R. The role of sinus imaging in the treatment of chronic cough in adults. Chest. 1999;116(5):1287-91. [pmid: 10559089].
Pratter MR, Bartter T, Akers S, et al. An algorithmic approach to chronic cough. Ann Intern Med. 1993;119(10):977-83. [pmid: 8214994].
Primbs K. Therapeutic activity of ambroxol theophyllinacetate in chronic obstructive pulmonary diseases. Clin Ther. 1985;7(6):733-6. [pmid: 4075364].
Ryan NM, Vertigan AE, Bone S, et al. Cough reflex sensitivity improves with speech language pathology management of refractory chronic cough. Cough. 2010;6:5. [pmid: 20663225].
Saunders DC. Trial of an anti-tussive preparation in droplet form. Practitioner. 1961;186:367-9. [pmid: 13746793].
Sawada S, Suehisa H, Yamashita M. Inhalation of corticosteroid and beta-agonist for persistent cough following pulmonary resection. Gen Thorac Cardiovasc Surg. 2012;60(5):285-8. [pmid: 22453538].
Singh VK. Clinical trial with ‘ZeeTuss’ - A herbal cough syrup in varieties of cough. JK Practitioner. 2000;7(3):214-217.
Tan NC, Ngoh SHA, Teo SSH, et al. Impact of cigarette smoking on symptoms and quality of life of adults with asthma managed in public primary care clinics in Singapore: a questionnaire study. Primary Care Respiratory Journal. 2012;21(1):90-93.
Tattersall AB, Bridgman KM, Huitson A. Irish general practice study of acetylcysteine (Fabrol) in chronic bronchitis. J Int Med Res. 1984;12(2):96-101. [pmid: 6373444].
Tattersall AB, Bridgman KM, Huitson A. Acetylcysteine (Fabrol) in chronic bronchitis—a study in general practice. J Int Med Res. 1983;11(5):279-84. [pmid: 6642068].
Toop LJ, Howie JG, Paxton FM. Night cough and general practice research. J R Coll Gen Pract. 1986;36(283):74-7. [pmid: 3712337].
Vernon M, Leidy NK, Nacson A, et al. Measuring cough severity: Perspectives from the literature and from patients with chronic cough. Cough. 2009;5:5. [pmid: 19298650].