# Included Studies

Aliprandi P, Castelli C, Bernorio S, et al. Levocloperastine in the treatment of chronic nonproductive cough: comparative efficacy versus standard antitussive agents. Drugs Exp Clin Res. 2004;30(4):133-41. [pmid: 15553659].
Archer LN, Simpson H. Night cough counts and diary card scores in asthma. Arch Dis Child. 1985;60(5):473-4. [pmid: 4015154].
Au DH, Blough DK, Kirchdoerfer L, et al. Development of a quantifiable symptom assessment tool for patients with chronic bronchitis: the Chronic Bronchitis Symptoms Assessment Scale. COPD. 2005;2(2):209-16. [pmid: 17136947].
Aversa C, Cazzola M, Clini V, et al. Clinical trial of the efficacy and safety of moguisteine in patients with cough associated with chronic respiratory diseases. Drugs Exp Clin Res. 1993;19(6):273-9. [pmid: 8013271].
Baiardini I, Braido F, Fassio O, et al. A new tool to assess and monitor the burden of chronic cough on quality of life: Chronic Cough Impact Questionnaire. Allergy. 2005;60(4):482-8. [pmid: 15727580].
Barnabe R, Berni F, Clini V, et al. The efficacy and safety of moguisteine in comparison with codeine phosphate in patients with chronic cough. Monaldi Arch Chest Dis. 1995;50(2):93-7. [pmid: 7613554].
Barry SJ, Dane AD, Morice AH, et al. The automatic recognition and counting of cough. Cough. 2006;2:8. [pmid: 17007636].
Berkhof FF, Boom LN, ten Hertog NE, et al. The validity of the Leicester Cough Questionnaire in COPD patients with chronic cough. Health Qual Life Outcomes. Jan. 9. 2012;10:4. [pmid: 22230731].
Birring SS, Fleming T, Matos S, et al. The Leicester Cough Monitor: preliminary validation of an automated cough detection system in chronic cough. Eur Respir J. 2008;31(5):1013-8. [pmid: 18184683].
Birring SS, Matos S, Patel RB, et al. Cough frequency, cough sensitivity and health status in patients with chronic cough. Respir Med. 2006;100(6):1105-9. [pmid: 16266801].
Birring SS, Prudon B, Carr AJ, et al. Development of a symptom specific health status measure for patients with chronic cough: Leicester Cough Questionnaire (LCQ). Thorax. 2003;58(4):339-43. [pmid: 12668799].
Braido F, Baiardini I, Tarantini F, et al. Chronic cough and QoL in allergic and respiratory diseases measured by a new specific validated tool-CCIQ. J Investig Allergol Clin Immunol. 2006;16(2):110-6. [pmid: 16689184].
Cass LJ, Frederik WS. Quantitative comparison of cough-suppressing effects of romilar and other antitussives. J Lab Clin Med. 1956;48(6):879-85. [pmid: 13376983].
Cass LJ, Frederick WS, Andosca JB. Quantitative comparison of dextromethorphan hydrobromide and codeine. American Journal of the Medical Sciences. 1954;227(3):291-6. [pmid: 13138597].
Cass LJ, Frederik WS. Evaluation of a new antitussive agent. New England Journal of Medicine. 1953;249(4):132-6. [pmid: 13063699].
Chang AB, Newman RG, Carlin JB, et al. Subjective scoring of cough in children: parent-completed vs child-completed diary cards vs an objective method. Eur Respir J. 1998;11(2):462-6. [pmid: 9551755].
Chang AB, Newman RG, Phelan PD, et al. A new use for an old Holter monitor: an ambulatory cough meter. Eur Respir J. 1997;10(7):1637-9. [pmid: 9230259].
Chang AB, Phelan PD, Robertson CF, et al. Relation between measurements of cough severity. Arch Dis Child. 2003;88(1):57-60. [pmid: 12495964].
Chang AB, Robertson CF, Van Asperen PP, et al. A multi-centre study on chronic cough in children: burden and etiologies based on a standardized management pathway. Chest. 2012. Epub ahead of print. [pmid: 22459773].
Chaudhuri R, McMahon AD, Thomson LJ, et al. Effect of inhaled corticosteroids on symptom severity and sputum mediator levels in chronic persistent cough. J Allergy Clin Immunol. 2004;113(6):1063-70. [pmid: 15208586].
Chernecky C, Sarna L, Waller JL, et al. Assessing coughing and wheezing in lung cancer: a pilot study. Oncol Nurs Forum. 2004;31(6):1095-101. [pmid: 15547632].
Clarke SW, Lopez-Vidriero MT, Pavia D, et al. The effect of sodium 2-mercapto-ethane sulphonate and hypertonic saline aerosols on bronchial clearance in chronic bronchitis. Br J Clin Pharmacol. 1979;7(1):39-44. [pmid: 104724].
Corrigan DL, Paton JY. Pilot study of objective cough monitoring in infants. Pediatr Pulmonol. 2003;35(5):350-7. [pmid: 12687591].
Coyle MA, Keenan DB, Henderson LS, et al. Evaluation of an ambulatory system for the quantification of cough frequency in patients with chronic obstructive pulmonary disease. Cough. 2005;1:3. [pmid: 16270923].
Crawford B, Monz B, Hohlfeld J, et al. Development and validation of a cough and sputum assessment questionnaire. Respir Med. 2008;102(11):1545-55. [pmid: 18662868].
Dales RE, White J, Bhumgara C, et al. Parental reporting of childrens' coughing is biased. Eur J Epidemiol. 1997;13(5):541-5. [pmid: 9258566].
De Vito Dabbs A, Hoffman LA, Dauber JH, et al. Evaluating the reliability and validity of the Questionnaire for Lung Transplant Patients. Prog Transplant. 2002;12(3):191-8. quiz 9-200. [pmid: 12371045].
Decalmer SC, Webster D, Kelsall AA, et al. Chronic cough: how do cough reflex sensitivity and subjective assessments correlate with objective cough counts during ambulatory monitoring?. Thorax. 2007;62(4):329-34. [pmid: 17101736].
Del Donno M, Aversa C, Corsico R, et al. Efficacy and safety of moguisteine in comparison with dextromethorphan in patients with persistent cough. Drug Investig. 1994;7(2):93-100.
Dicpinigaitis PV, Tso R, Banauch G. Prevalence of depressive symptoms among patients with chronic cough. Chest. 2006;130(6):1839-43. [pmid: 17167006].
Dierckx P, Leblanc G, Decoster A, et al. Double-blind study of glaucine in chronic cough. Int J Clin Pharmacol Ther Toxicol. 1981;19(9):396-9. [pmid: 7028646].
Diwan J, Dhand R, Jindal SK, et al. A comparative randomized double-blind clinical trial of isoaminile citrate and chlophedianol hydrochloride as antitussive agents. Int J Clin Pharmacol Ther Toxicol. 1982;20(8):373-5. [pmid: 6749701].
Doherty MJ, Mister R, Pearson MG, et al. Capsaicin responsiveness and cough in asthma and chronic obstructive pulmonary disease. Thorax. 2000;55(8):643-9. [pmid: 10899239].
Doherty MJ, Mister R, Pearson MG, et al. Capsaicin induced cough in cryptogenic fibrosing alveolitis. Thorax. 2000;55(12):1028-32. [pmid: 11083888].
Dueholm M, Nielsen C, Thorshauge H, et al. N-acetylcysteine by metered dose inhaler in the treatment of chronic bronchitis: a multi-centre study. Respir Med. 1992;86(2):89-92. [pmid: 1615189].
Falconer A, Oldman C, Helms P. Poor agreement between reported and recorded nocturnal cough in asthma. Pediatr Pulmonol. 1993;15(4):209-11. [pmid: 8469572].
Faniran AO, Peat JK, Woolcock AJ. Measuring persistent cough in children in epidemiological studies: development of a questionnaire and assessment of prevalence in two countries. Chest. 1999;115(2):434-9. [pmid: 10027444].
Faruqi S, Thompson R, Wright C, et al. Quantifying chronic cough: objective versus subjective measurements. Respirology. 2011;16(2):314-20. [pmid: 21054670].
Field SK, Conley DP, Thawer AM, et al. Effect of the management of patients with chronic cough by pulmonologists and certified respiratory educators on quality of life: a randomized trial. Chest. 2009;136(4):1021-8. [pmid: 19349387].
Fisman EZ, Shapira I, Motro M, et al. The combined cough frequency/severity scoring: a new approach to cough evaluation in clinical settings. J Med. 2001;32(3-4):181-7. [pmid: 11563816].
Fletcher KE, French CT, Irwin RS, et al. A prospective global measure, the Punum Ladder, provides more valid assessments of quality of life than a retrospective transition measure. J Clin Epidemiol. 2010;63(10):1123-31. [pmid: 20303709].
Freestone C, Eccles R. Assessment of the antitussive efficacy of codeine in cough associated with common cold. J Pharm Pharmacol. 1997;49(10):1045-9. [pmid: 9364418].
French CL, Irwin RS, Curley FJ, et al. Impact of chronic cough on quality of life. Arch Intern Med. 1998;158(15):1657-61. [pmid: 9701100].
French CT, Irwin RS, Fletcher KE, et al. Evaluation of a cough-specific quality-of-life questionnaire. Chest. 2002;121(4):1123-31. [pmid: 11948042].
Fuller P, Picciotto A, Davis M, et al. Cough and sleep in inner-city children. Eur Respir J. 1998;12(2):426-31. [pmid: 9727796].
Gastpar H, Criscuolo D, Dieterich HA. Efficacy and tolerability of glaucine as an antitussive agent. Curr Med Res Opin. 1984;9(1):21-7. [pmid: 6373156].
Guyatt GH, Townsend M, Kazim F, et al. A controlled trial of ambroxol in chronic bronchitis. Chest. 1987;92(4):618-20. [pmid: 3308343].
Hamutcu R, Francis J, Karakoc F, et al. Objective monitoring of cough in children with cystic fibrosis. Pediatr Pulmonol. 2002;34(5):331-5. [pmid: 12357476].
Hartnick CJ, Zurakowski D, Haver K. Validation of a pediatric cough questionnaire. Ear Nose Throat J. 2009;88(11):1213-7. [pmid: 19924664].
Holmes PW, Barter CE, Pierce RJ. Chronic persistent cough: use of ipratropium bromide in undiagnosed cases following upper respiratory tract infection. Respir Med. 1992;86(5):425-9. [pmid: 1462022].
Hoskyns EW, Thomson A, Decker E, et al. Effect of controlled release salbutamol on nocturnal cough in asthma. Arch Dis Child. 1991;66(10):1209-12. [pmid: 1953004].
Hsu JY, Stone RA, Logan-Sinclair RB, et al. Coughing frequency in patients with persistent cough: assessment using a 24 hour ambulatory recorder. Eur Respir J. 1994;7(7):1246-53. [pmid: 7925902].
Huisman AN, Wu MZ, Uil SM, et al. Reliability and validity of a Dutch version of the Leicester Cough Questionnaire. Cough. 2007;3:3. [pmid: 17313670].
Irwin RS, Zawacki JK, Wilson MM, et al. Chronic cough due to gastroesophageal reflux disease: failure to resolve despite total near-total elimination of esophageal acid. Chest. 2002;121(4):1132-40. [pmid: 11948043].
Jackson IM, Barnes J, Cooksey P. Efficacy and tolerability of oral acetylcysteine (Fabrol) in chronic bronchitis: a double-blind placebo controlled study. J Int Med Res. 1984;12(3):198-206. [pmid: 6376210].
Jones RM, Hilldrup S, Hope-Gill BD, et al. Mechanical induction of cough in Idiopathic Pulmonary Fibrosis. Cough. 2011;7:2. [pmid: 21477349].
Kalpaklioglu AF, Kara T, Kurtipek E, et al. Evaluation and impact of chronic cough: comparison of specific vs generic quality-of-life questionnaires. Ann Allergy Asthma Immunol. 2005;94(5):581-5. [pmid: 15945562].
Kelsall A, Decalmer S, McGuiness K, et al. Dex differences and predictors of objective cough frequency in chronic cough. Thorax. 2009;64(5):393-8. [pmid: 19131447].
Kelsall A, Decalmer S, Webster D, et al. How to quantify coughing: correlations with quality of life in chronic cough. Eur Respir J. 2008;32(1):175-9. [pmid: 18287128].
Kelsall A, Houghton LA, Jones H, et al. A novel approach to studying the relationship between subjective and objective measures of cough. Chest. 2011;139(3):569-75. [pmid: 20864619].
Key AL, Holt K, Hamilton A, et al. Objective cough frequency in Idiopathic Pulmonary Fibrosis. Cough. 2010;6:4. [pmid: 20565979].
Krahnke J, Gentile D, Angelini B, et al. Comparison of objective and subjective measurements of cough frequency in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2004;93(3):259-64. [pmid: 15478386].
Krajnik M, Damps-Konstanska I, Gorska L, et al. A portable automatic cough analyser in the ambulatory assessment of cough. Biomed Eng Online. 2010;9:17. [pmid: 20226089].
Leconte S, Liistro G, Lebecque P, et al. The objective assessment of cough frequency: accuracy of the LR102 device. Cough. 2011;7(1):11. [pmid: 22132691].
Lilienfield LS, Rose JC, Princiotto JV. Antitussive activity of diphenhydramine in chronic cough. Clin Pharmacol Ther. 1976;19(4):421-5. [pmid: 773581].
Luporini G, Barni S, Marchi E, et al. Efficacy and safety of levodropropizine and dihydrocodeine on nonproductive cough in primary and metastatic lung cancer. Eur Respir J. 1998;12(1):97-101. [pmid: 9701421].
Ma W, Yu L, Wang Y, et al. Changes in health-related quality of life and clinical implications in Chinese patients with chronic cough. Cough. 2009;5:7. [pmid: 19781068].
Marchant J, Masters IB, Champion A, et al. Randomised controlled trial of amoxicillin clavulanate in children with chroni wet cough. Thorax. 2012;67(8):689-93. [pmid: 22628120].
Marsden PA, Smith JA, Kelsall AA, et al. A comparison of objective and subjective measures of cough in asthma. J Allergy Clin Immunol. 2008;122(5):903-7. [pmid: 18842290].
Matos S, Birring SS, Pavord ID, et al. An automated system for 24-h monitoring of cough frequency: the Leicester Cough Monitor. IEEE Trans Biomed Eng. 2007;54(8):1472-9. [pmid: 17694868].
Matthys H, Bleicher B, Bleicher U. Dextromethorphan and codeine: objective assessment of antitussive activity in patients with chronic cough. J Int Med Res. 1983;11(2):92-100. [pmid: 6852361].
Matts SG. A trial of Lotussin and linctus diphenhydramine in patients wth an irritant cough. J Int Med Res. 1977;5(6):470-2. [pmid: 338397].
Monz BU, Sachs P, McDonald J, et al. Responsiveness of the cough and sputum assessment questionnaire in exacerbations of COPD and chronic bronchitis. Respir Med. 2010;104(4):534-41. [pmid: 19917525].
Morice AH, Menon MS, Mulrennan SA, et al. Opiate therapy in chronic cough. Am J Respir Crit Care Med. 2007;175(4):312-5. [pmid: 17122382].
Mukaida K, Hattori N, Kondo K, et al. A pilot study of the multiherb Kampo medicine bakumondoto for cough in patients with chronic obstructive pulmonary disease. Phytomedicine. 2011;18(8-9):625-9. [pmid: 21177084].
Murray MP, Turnbull K, MacQuarrie S, et al. Validation of the Leicester Cough Questionnaire in non-cystic fibrosis bronchiectasis. Eur Respir J. 2009;34(1):125-31. [pmid: 19196812].
Mwachari C, Nduba V, Nguti R, et al. Validation of a new clinical scoring system for acute bronchitis. Int J Tuberc Lung Dis. 2007;11(11):1253-9. [pmid: 17958990].
Nandha D, Goodyer L, Woodruffe-Peacock C. Diary cards and the assessment of cough symptoms in community pharmacies. Pharm World Sci. 2000;22(1):17-20. [pmid: 10815295].
Newcombe PA, Sheffield JK, Chang AB. Minimally important change in a Parent-Proxy Quality-of-Life questionnaire for pediatric chronic cough. Chest. 2011;139(3):576-80. [pmid: 20947650].
Newcombe PA, Sheffield JK, Juniper EF, et al. Development of a parent-proxy quality-of-life chronic cough-specific questionnaire: clinical impact vs psychometric evaluations. Chest. 2008;133(2):386-95. [pmid: 18252913].
Newcombe PA, Sheffield JK, Juniper EF, et al. Validation of a parent-proxy quality of life questionnaire for paediatric chronic cough (PC-QOL). Thorax. 2010;65(9):819-23. [pmid: 20805179].
Nieto L, de Diego A, Perpina M, et al. Cough reflex testing with inhaled capsaicin in the study of chronic cough. Respir Med. 2003;97(4):393-400. [pmid: 12693800].
Novitsky YW, Zawacki JK, Irwin RS, et al. Chronic cough due to gastroesophageal reflux disease: efficacy of antireflux surgery. Surg Endosc. 2002;16(4):567-71. [pmid: 11972189].
O'Connell F, Thomas VE, Pride NB, et al. Capsaicin cough sensitivity decreases with successful treatment of chronic cough. Am J Respir Crit Care Med. 1994;150(2):374-80. [pmid: 8049818].
Parvez L, Vaidya M, Sakhardande A, et al. Evaluation of antitussive agents in man. Pulm Pharmacol. 1996;9(5-6):299-308. [pmid: 9232667].
Paul IM, Wai K, Jewell SJ, et al. Evaluation of a new self-contained, ambulatory, objective cough monitor. Cough. 2006;2:7. [pmid: 17005042].
Polley L, Yaman N, Heaney L, et al. Impact of cough across different chronic respiratory diseases: comparison of two cough-specific health-related quality of life questionnaires. Chest. 2008;134(2):295-302. [pmid: 18071022].
Raj AA, Pavord DI, Birring SS. Clinical cough IV: what is the minimal important difference for the Leicester Cough Questionnaire?. Handb Exp Pharmacol. 2009;(187):311-20. [pmid: 18825348].
Ramsay J, Wright C, Thompson R, et al. Assessment of antitussive efficacy of dextromethorphan in smoking related cough: objective vs. subjective measures. Br J Clin Pharmacol. 2008;65(5):737-41. [pmid: 18279476].
Reid JJ. Double-blind trial of ketotifen in childhood chronic cough and wheeze. Immunol Allergy Pract. 1989;11(4):143-50.
Ribeiro M, Pereira CA, Nery LE, et al. High-dose inhaled beclomethasone treatment in patients with chronic cough: a randomized placebo-controlled study. Ann Allergy Asthma Immunol. 2007;99(1):61-8. [pmid: 17650832].
Ruhle KH, Criscuolo D, Dieterich HA, et al. Objective evaluation of dextromethorphan and glaucine as antitussive agents. Br J Clin Pharmacol. 1984;17(5):521-4. [pmid: 6375709].
Sabot G, Bagnato A, Frigerio G. Controlled evaluation of the antitussive activity of viminol p-hydroxybenzoate. Int J Clin Pharmacol Biopharm. 1977;15(4):181-3. [pmid: 323163].
Sevelius H, McCoy JF, Colmore JP. Dose response to codeine in patients with chronic cough. Clin Pharmacol Ther. 1971;12(3):449-55. [pmid: 4936034].
Shaheen NJ, Crockett SD, Bright SD, et al. Randomised clinical trial: high-dose acid suppression for chronic cough—a double-blind, placebo-controlled study. Aliment Pharmacol Ther. 2011;33(2):225-34. [pmid: 21083673].
Simon SW. A comparative study of two new non-narcotic antitussive drugs. Ohio Med. 1957;53(12):1426-7. [pmid: 13493953].
Simon SW. Symptomatic treatment of asthmatic bronchitis. J Am Geriatr Soc. 1960;8:107-11. [pmid: 14446944].
Singapuri A, McKenna S, Brightling CE. The utility of the mannitol challenge in the assessment of chronic cough: a pilot study. Cough. 2008;4:10. [pmid: 19017380].
Smith J, Owen E, Earis J, et al. Cough in COPD: correlation of objective monitoring with cough challenge and subjective assessments. Chest. 2006;130(2):379-85. [pmid: 16899835].
Smith J, Owen E, Earis J, et al. Effect of codeine on objective measurement of cough in chronic obstructive pulmonary disease. J Allergy Clin Immunol. 2006;117(4):831-5. [pmid: 16630941].
Smith JA, Owen EC, Jones AM, et al. Objective measurement of cough during pulmonary esacerbations in adults with cystic fibrosis. Thorax. 2006;61(5):425-9. [pmid: 16449266].
Smith JA, Earis JE, Woodcock AA. Establishing a gold standard for manual cough counting: video versus digital audio recordings. Cough. 2006;2:6. [pmid: 16887019].
Tanaka S, Hirata K, Kurihara N, et al. Effect of loratadine, an H1 antihistamine, on induced cough in non-asthmatic patients with chronic cough. Thorax. 1996;51(8):810-4. [pmid: 8795669].
Thomas JS, Lyons HA, Shepherd DA. D.A.T.A.—an advanced automated electronic cough counting system for the evaluation of antitussive agents. Curr Ther Res Clin Exp. 1978;23(1):66-77.
Vakil BJ, Mehta AJ, Prajapat KD. Trial of pipazethate as an antitussive. Clin Pharmacol Ther. 1966;7(4):515-9. [pmid: 5328471].
van Asperen PP, McKay KO, Mellis CM, et al. A multicentre randomized placebo-controlled double-blind study on the efficacy of Ketotifen in infants with chronic cough or wheeze. J Paediatr Child Health. 1992;28(6):442-6. [pmid: 1466940].
van Hengstum M, Festen J, Beurskens C, et al. The effect of positive expiratory pressure versus forced expiration technique on tracheobronchial clearance in chronic bronchitics. Scand J Gastroenterol Suppl. 1988;143:114-8. [pmid: 3291088].
Vernon M, Kline Leidy N, Nacson A, et al. Measuring cough severity: development and pilot testing of a new seven-item cough severity patient-reported outcome measure. Ther Adv Respir Dis. 2010;4(4):199-208. [pmid: 20519373].
Vertigan AE, Theodoros DG, Gibson PG, et al. Efficacy of speech pathology management for chronic cough: a randomised placebo controlled trial of treatment efficacy. Thorax. 2006;61(12):1065-9. [pmid: 16844725].
Wei W, Yu L, Wang Y, et al. Efficacy and safety of modified sequential three-step empirical therapy for chronic cough. Respirology. 2010;15(5):830-6. [pmid: 20546197].
Wojcicki J, Samochowiec L, Szwed G, et al. The use of Duopect as expectorant–antitussive agent. Arch Immunol Ther Exp (Warsz). 1975;23(1):135-42. [pmid: 1090275].
Woodcock A, McLeod RL, Sadeh J, et al. The efficacy of a NOP1 agonist (SCH486757) in subacute cough. Lung. 2010;188(Suppl 1):S47-52. [pmid: 19937046].
Woolf CR, Rosenberg A. Objective assessment of cough suppressants under clinical conditions using a tape recorder system. Thorax. 1964;19:125-30. [pmid: 14128569].
Yousaf N, Monteiro W, Parker D, et al. Long-term low-dose erythromycin in patients with unexplained chronic cough: a double-blind placebo controlled trial. Thorax. 2010;65(12):1107-10. [pmid: 20965928].
Zihlif N, Paraskakis E, Lex C, et al. Correlation between cough frequency and airway inflammation in children with primary ciliary dyslinesia. Pediatr Pulmonol. 2005;39(6):551-7. [pmid: 15806596].