# Data Abstraction Elements

## I Study Characteristics

- Study Dates
- Study Sites
- Geographical Location (Select all that apply)
- Funding Source (Select all that apply)
- Setting (Select all that apply)
- Enrollment Approach (Select all that apply)
  ○ Consecutive patients
  ○ Convenience sample (not explicitly consecutive)
  ○ Not reported/unclear
  ○ Other – Describe
- Inclusion Criteria: Copy/paste inclusion criteria as reported in the article.
- Exclusion Criteria: Copy/paste exclusion criteria as reported in the article.
- Applicability of Key Questions (Indicate whether the article is applicable to each key question below.)
  ○ Which populations are included in this study? (Select all that apply)
    ■ Adults and adolescents (≥14 yrs) with cough
    ■ Children (<14 years of age) with cough
    ■ Adults and adolescents (≥14 yrs) with chronic cough
    ■ Children (<14 years of age) with chronic cough
  ○ Underlying etiology of cough symptoms in the study population:
    ■ If Unexplained/idiopathic (Select all that apply)
      - Absence of signs of symptoms of an etiology (NEG S/SX) –Describe
      - Negative diagnostic evaluation (NEG DX) – Describe diagnostic evaluation
      - Lack of response to trial of empiric therapy (NEG EMP TX) – Describe empiric therapy trial and response
      - Other – Describe
    ■ If Unresponsive/Refractory/Intractable: (Select all that apply)
      - If Known/suspected etiology (Select an answer)
        ○ Chronic obstructive pulmonary disease (COPD)
        ○ GERD
        ○ Asthma
        ○ Cough-variant asthma
        ○ UACS (postnasal drip, allergic rhinitis)
        ○ Interstitial lung disease (sarcoid, etc.)
        ○ Chronic bronchitis
        ○ Bronchiectasis, Cystic Fibrosis
        ○ Neuromuscular disease (Duchenne muscular dystrophy, ACS, SCI, etc.)
        ○ Unexplained
        ○ Other – Describe
      - Positive signs/symptoms – Describe
      - Positive diagnostic evaluation – Describe
      - Other – Describe
      - Specific therapy trial(s) and response – Describe
  ○ Chronicity – Describe minimum duration required (in weeks)
  ○ Key Question 1 - In adults and adolescents (≥14 years of age) and children (<14 years of age), what is the comparative diagnostic accuracy, therapeutic efficacy, and patient outcome efficacy of instruments used to assess cough? (Yes/No, This is not a KQ1 article)
  ○ Key Question 2 - In adults and adolescents (≥14 years of age) and children (<14 years of age), what are the comparative safety and effectiveness of nonspecific (or symptomatic) therapies to treat patients with chronic cough?
    ■ In patients with unexplained chronic cough
    ■ In patients with refractory cough with a known underlying etiology (Yes/No, This is not a KQ2 article)
- Study Enrollment/Study Completion
  ○ Assessed for eligibility (N)
  ○ Eligible (N)
  ○ Randomized (N)
  ○ Completed follow-up (N)
  ○ Included in primary outcome analysis (N)
- Comments

## II KQ 1 Instruments

- Author
- Year
- Total N
- Was there a longitudinal component to this study (Yes/No)
- Patient Population – Describe
- Instruments – Include each instrument only once, either under Index or Reference Tests.
  ○ Index Test/Instrument being evaluated
    ■ Cough count (by a human)
    ■ Electronic cough recorder (Sound or pressure)
    ■ Video cough recorder
    ■ Tussigenic challenge
    ■ Cough diaries
    ■ Score
    ■ VAS
    ■ Global Rating Scale
    ■ If Questionnaire(s) – Questionnaire(s) Name
      - Leicester Cough Questionnaire
      - Cough-specific QoL
      - Chronic Bronchitis Symptoms Assessment Scale
      - Chronic Cough Impact Questionnaire
      - Lung Cancer Cough Questionnaire
      - Cough & Sputum Assessment
      - (A predictive questionnaire)
      - Punum Ladders
      - Adverse Cough Outcome Survey
      - Pediatric Cough Questionnaire
      - Hull Airway Reflux Questionnaire
      - Parent Prox QoL Questionnaire (PC-QoL)
      - Disabkids Questionnaire subscale
      - Cough Severity Diary
    ■ Other – Describe
  ○ Reference Test/Comparator
    ■ Cough count (by a human)
    ■ Electronic cough recorder (Sound or pressure)
    ■ Video cough recorder
    ■ Tussigenic challenge
    ■ Cough diaries
    ■ Score
    ■ VAS
    ■ Global Rating Scale
    ■ If Questionnaire(s) – Questionnaire(s) Name
      - Leicester Cough Questionnaire
      - Cough-specific QoL
      - Chronic Bronchitis Symptoms Assessment Scale
      - Chronic Cough Impact Questionnaire
      - Lung Cancer Cough Questionnaire
      - Cough & Sputum Assessment
      - (A predictive questionnaire)
      - Punum Ladders
      - Adverse Cough Outcome Survey
      - Pediatric Cough Questionnaire
      - Hull Airway Reflux Questionnaire
      - Parent Prox QoL Questionnaire (PC-QoL)
      - Disabkids Questionnaire subscale
      - Cough Severity Diary
    ■ Other – Describe
- Results – Specify what is being compared along with results
- Comments

## III KQ 1 Quality Assessment

- QUADAS-2 Tool for Quality Assessment of Studies of Diagnostic Accuracy
- Rate each risk of bias item listed below as “Yes,” “No,” or “Unclear.” “Yes” indicates low risk of bias, and “No” indicates high risk of bias. After considering each of the quality items, give the study an overall rating of “High risk of bias,” “Low risk of bias,” or “Unclear.” Detailed instructions for each item are provided below. A user's guide explaining each question and how to score your responses is available in the QUADAS-2 article here: www.bris.ac.uk/quadas/quadas-2/
  ○ Describe methods of patient selection: Describe included patients (prior testing, presentation, intended use of index test and setting)
  ○ Describe the index test and how it was conducted and interpreted
  ○ Describe the reference standard and how it was conducted and interpreted
  ○ Describe any patients who did not receive the index test(s) and/or reference standard or who were excluded from the 2×2 table (refer to flow diagram):
    Describe the time interval and any interventions between index test(s) and reference standard
  ○ Was a consecutive or random sample of patients enrolled?
  ○ Were the index test results interpreted without knowledge of the results of the reference standard?
  ○ Is the reference standard likely to correctly classify the target condition?
  ○ Was there an appropriate interval between index test(s) and reference standard?
  ○ Was a case-control design avoided?
  ○ If a threshold was used, was it pre-specified?
  ○ Were the reference standard results interpreted without knowledge of the results of the index test?
  ○ Did all patients receive a reference standard?
  ○ Did the study avoid inappropriate exclusions?
  ○ Did all patients receive the same reference standard?
  ○ Were all patients included in the analysis?
  ○ Could the selection of patients have introduced bias?
  ○ Could the conduct or interpretation of the index test have introduced bias?
  ○ Could the reference standard, its conduct, or its interpretation have introduced bias?
  ○ Could the patient flow have introduced bias?
  ○ Are there concerns that the included patients do not match the review question?
  ○ Are there concerns that the index test, its conduct, or interpretation differ from the review question?
  ○ Are there concerns that the target condition as defined by the reference standard does not match the review question?
- Overall study rating
  ○ Risk of bias is judged as “low”, “high”, or “unclear”. If the answers to all questions in a domain are “yes”, then risk of bias can be judged low. If any question is answered “no”, potential bias exists and previously determined guidelines must be used to make a judgment. The “unclear” category should only be used when insufficient data are reported to permit a judgment.
- Comments

## IV KQ 1 Applicability Assessment

- Population (P)
  ○ Study population poorly described
  ○ Inadequate diagnostic evaluation of cough
- Intervention (I)
  ○ Instrument not well described
  ○ Highly selected instrument or level of training/proficiency not widely available
  ○ Doses not reflected in current practice
  ○ Monitoring practices/visit frequency not in typical practice (e.g., frequent contact, incentives)
  ○ Older versions of an intervention no longer in common use
  ○ Cointerventions likely to modify effectiveness of treatment
- Comparator (C)
  ○ Inadequate comparison therapy
  ○ Comparator(s) not well described
  ○ Use of substandard alternative therapy (e.g., standard of treatment not from current practice)
- Outcomes (O)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Uses lab assessment such as tussigenic challenge as main outcome
  ○ Short-term or surrogate outcomes
- Setting (S)
  ○ Conducted outside of the US and practices not well described or widely divergent relative to US practices
  ○ Not widely accessible technology
- Comments

## V KQ 2 All Study Arms

- Study type
  ○ RCT
  ○ Cohort
  ○ Crossover
- Common Co-interventions – List common co-interventions across all arms
- Placebo or Control – Treatment Type
  ○ Placebo
  ○ No treatment control
  ○ If Usual care control
    ■ Is the planned usual care identical for the intervention arm(s) and the comparator arm?
  ○ Other – Describe
  ○ Not applicable
- Active Treatment Arm 1 – Treatment Type
  ○ Pharmacologic Antitussive
    ■ Anesthetics (e.g., benzonatate)
    ■ Opiates (e.g., codeine, hydrocodone)
    ■ Other (e.g., Dextromethorphan) – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Nonpharmacologic Antitussive
    ■ Foods (e.g., honey, tea, lemon, liquor)
    ■ Psychological (e.g., cognitive behavioral therapy)
    ■ Alternative (e.g., acupuncture, tai chi, yoga, meditation)
    ■ Multidimensional (e.g., speech therapy)
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Pharmacologic Protussive
    ■ Expectorants (e.g., guaifenesin)
    ■ Mucolytic or mucus modifying (e.g., acetylcysteine, dornase alfa inhaled)
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Nonpharmacologic Protussive
    ■ Physical
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Not applicable
- Active Treatment Arm 2 – Treatment Type
  ○ Pharmacologic Antitussive
    ■ Anesthetics (e.g., benzonatate)
    ■ Opiates (e.g., codeine, hydrocodone)
    ■ Other (e.g., Dextromethorphan) – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Nonpharmacologic Antitussive
    ■ Foods (e.g., honey, tea, lemon, liquor)
    ■ Psychological (e.g., cognitive behavioral therapy)
    ■ Alternative (e.g., acupuncture, tai chi, yoga, meditation)
    ■ Multidimensional (e.g., speech therapy)
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Pharmacologic Protussive
    ■ Expectorants (e.g., guaifenesin)
    ■ Mucolytic or mucus modifying (e.g., acetylcysteine, dornase alfa inhaled)
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Nonpharmacologic Protussive
    ■ Physical
    ■ Other – Describe
    ■ Specific medication or treatment names
    ■ Frequency (times per day)
    ■ Duration
    ■ Dosage
  ○ Not applicable
- Comments

## VI KQ 2 Baseline Characteristics

- Number of Subjects
  ○ Total
    ■ Gender N
      - Total
      - Female
      - Male
    ■ Age N
      - Infants <6 mo
      - Children 6mo - 2yrs
      - Children 3-6 yrs
      - Children 7-13 yrs
      - Adults/Adolescents 14-64 yrs
      - Adults 18+
      - Adults ≥ 65 yrs
      - Other age category – Specify age category used
  ○ Active Treatment Arm 1 – Choose one (Pharmacologic antitussives/Nonpharmacologic antitussives/Pharmacologic protussives/Nonpharmacologic protussives)
    ■ Gender N
      - Total
      - Female
      - Male
    ■ Age N
      - Infants <6 mo
      - Children 6mo - 2yrs
      - Children 3-6 yrs
      - Children 7-13 yrs
      - Adults/Adolescents 14-64 yrs
      - Adults 18+
      - Adults ≥ 65 yrs
      - Other age category – Specify age category used
  ○ Active Treatment Arm 2 – Choose one (Pharmacologic antitussives/Nonpharmacologic antitussives/Pharmacologic protussives/Nonpharmacologic protussives)
    ■ Gender N
      - Total
      - Female
      - Male
    ■ Age N
      - Infants <6 mo
      - Children 6mo - 2yrs
      - Children 3-6 yrs
      - Children 7-13 yrs
      - Adults/Adolescents 14-64 yrs
      - Adults 18+
      - Adults ≥ 65 yrs
      - Other age category – Specify age category used
  ○ Placebo or Control – Choose one (Placebo/No treatment control/Usual treatment control/Other)
    ■ Gender N
      - Total
      - Female
      - Male
    ■ Age N
      - Infants <6 mo
      - Children 6mo - 2yrs
      - Children 3-6 yrs
      - Children 7-13 yrs
      - Adults/Adolescents 14-64 yrs
      - Adults 18+
      - Adults ≥ 65 yrs
      - Other age category – Specify age category used
- Total Population
  ○ Age in Years
    ■ Total
      - Mean
      - Variability – Fill in which type
      - Median
      - Min
      - Max
    ■ Active Treatment Arm 1 – Choose one (Pharmacologic antitussives/Nonpharmacologic antitussives/Pharmacologic protussives/Nonpharmacologic protussives)
      - Mean
      - Variability – Fill in which type
      - Median
      - Min
      - Max
    ■ Active Treatment Arm 2 - Choose one (Pharmacologic antitussives/Nonpharmacologic antitussives/Pharmacologic protussives/Nonpharmacologic protussives)
      - Mean
      - Variability – Fill in which type
      - Median
      - Min
      - Max
    ■ Placebo or Control – Choose one (Placebo/No treatment control/Usual treatment control/Other)
      - Mean
      - Variability – Fill in which type
      - Median
      - Min
      - Max
  ○ Ethnicity
    ■ Total
      - Hispanic or Latino
      - Not Hispanic or Latino
    ■ Treatment Arm 1
      - Hispanic or Latino
      - Not Hispanic or Latino
    ■ Treatment Arm 2
      - Hispanic or Latino
      - Not Hispanic or Latino
    ■ Placebo or Control
      - Hispanic or Latino
      - Not Hispanic or Latino
  ○ Race
    ■ Total
      - Black/African American
      - American Indian or Alaska Native
      - Asian
      - Native Hawaiian or other Pacific Islander
      - White
      - Multiracial
      - Other – Describe
    ■ Treatment Arm 1
      - Black/African American
      - American Indian or Alaska Native
      - Asian
      - Native Hawaiian or other Pacific Islander
      - White
      - Multiracial
      - Other – Describe
    ■ Treatment Arm 2
      - Black/African American
      - American Indian or Alaska Native
      - Asian
      - Native Hawaiian or other Pacific Islander
      - White
      - Multiracial
      - Other – Describe
    ■ Placebo or Control
      - Black/African American
      - American Indian or Alaska Native
      - Asian
      - Native Hawaiian or other Pacific Islander
      - White
      - Multiracial
      - Other – Describe
- Baseline Characteristics
  ○ Baseline Characteristics
    ■ Total
      - Cough severity measure #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #3 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough frequency – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough duration – Describe
        ○ Mean
        ○ Median
        ○ SD
      - FEV1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Bronchoprovocation challenge – Describe
        ○ Mean
        ○ Median
        ○ SD
    ■ Treatment Arm 1
      - Cough severity measure #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #3 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough frequency – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough duration – Describe
        ○ Mean
        ○ Median
        ○ SD
      - FEV1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Bronchoprovocation challenge – Describe
        ○ Mean
        ○ Median
        ○ SD
    ■ Treatment Arm 2
      - Cough severity measure #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #3 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough frequency – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough duration – Describe
        ○ Mean
        ○ Median
        ○ SD
      - FEV1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Bronchoprovocation challenge – Describe
        ○ Mean
        ○ Median
        ○ SD
    ■ Placebo or Control
      - Cough severity measure #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough severity measure #3 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough frequency – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Cough duration – Describe
        ○ Mean
        ○ Median
        ○ SD
      - FEV1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #1 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Tussigenic Challenge #2 – Describe
        ○ Mean
        ○ Median
        ○ SD
      - Bronchoprovocation challenge – Describe
        ○ Mean
        ○ Median
        ○ SD
  ○ Patient Group Imbalance (Yes/No/Unclear)
  ○ Causes of Chronic Cough
    ■ Unexplained – If so, describe and provide numbers in table below
    ■ Known etiology
      - Total
        ○ Chronic obstructive pulmonary disease (COPD)
          ■ N
          ■ %
        ○ GERD
          ■ N
          ■ %
        ○ Asthma
          ■ N
          ■ %
        ○ Cough-variant asthma
          ■ N
          ■ %
        ○ UACS (postnasal drip, allergic rhinitis)
          ■ N
          ■ %
        ○ Interstitial lung disease (sarcoid, etc.)
          ■ N
          ■ %
        ○ Chronic bronchitis
          ■ N
          ■ %
        ○ Bronchiectasis, Cystic Fibrosis
          ■ N
          ■ %
        ○ Neuromuscular disease (Duchenne muscular dystrophy, ACS, SCI, etc)
          ■ N
          ■ %
        ○ Unexplained
          ■ N
          ■ %
        ○ Other – Describe
          ■ N
          ■ %
      - Treatment Arm 1
        ○ Chronic obstructive pulmonary disease (COPD)
          ■ N
          ■ %
        ○ GERD
          ■ N
          ■ %
        ○ Asthma
          ■ N
          ■ %
        ○ Cough-variant asthma
          ■ N
          ■ %
        ○ UACS (postnasal drip, allergic rhinitis)
          ■ N
          ■ %
        ○ Interstitial lung disease (sarcoid, etc.)
          ■ N
          ■ %
        ○ Chronic bronchitis
          ■ N
          ■ %
        ○ Bronchiectasis, Cystic Fibrosis
          ■ N
          ■ %
        ○ Neuromuscular disease (Duchenne muscular dystrophy, ACS, SCI, etc)
          ■ N
          ■ %
        ○ Unexplained
          ■ N
          ■ %
        ○ Other – Describe
          ■ N
          ■ %
      - Treatment Arm 2
        ○ Chronic obstructive pulmonary disease (COPD)
          ■ N
          ■ %
        ○ GERD
          ■ N
          ■ %
        ○ Asthma
          ■ N
          ■ %
        ○ Cough-variant asthma
          ■ N
          ■ %
        ○ UACS (postnasal drip, allergic rhinitis)
          ■ N
          ■ %
        ○ Interstitial lung disease (sarcoid, etc.)
          ■ N
          ■ %
        ○ Chronic bronchitis
          ■ N
          ■ %
        ○ Bronchiectasis, Cystic Fibrosis
          ■ N
          ■ %
        ○ Neuromuscular disease (Duchenne muscular dystrophy, ACS, SCI, etc)
          ■ N
          ■ %
        ○ Unexplained
          ■ N
          ■ %
        ○ Other – Describe
          ■ N
          ■ %
      - Placebo or Control
        ○ Chronic obstructive pulmonary disease (COPD)
          ■ N
          ■ %
        ○ GERD
          ■ N
          ■ %
        ○ Asthma
          ■ N
          ■ %
        ○ Cough-variant asthma
          ■ N
          ■ %
        ○ UACS (postnasal drip, allergic rhinitis)
          ■ N
          ■ %
        ○ Interstitial lung disease (sarcoid, etc.)
          ■ N
          ■ %
        ○ Chronic bronchitis
          ■ N
          ■ %
        ○ Bronchiectasis, Cystic Fibrosis
          ■ N
          ■ %
        ○ Neuromuscular disease (Duchenne muscular dystrophy, ACS, SCI, etc)
          ■ N
          ■ %
        ○ Unexplained
          ■ N
          ■ %
        ○ Other – Describe
          ■ N
          ■ %
- Comments

## VII KQ 2 Quality Assessment

- Study Type
  ○ If RCT
    ■ Was the assignment randomized? (Yes/No/Unclear)
    ■ Was the allocation to study groups, (and interventions) adequately concealed? (Yes/No/Unclear)
  ○ If Cohort
    ■ Any attempt to balance the allocation between the groups? (Yes/No/Unclear)
    ■ Were the criteria applied equally to all groups? (Yes/No/Unclear)
    ■ Was the selection of the comparison group appropriate? (Yes/No/Unclear)
    ■ Does the design or analysis control account for important confounding and modifying variables? (Yes/No/Unclear)
    ■ In cohort studies, is the length of follow-up the same between the groups? (Yes/No/Unclear)
    ■ Are confounding variables assessed using valid and reliable measures, implemented consistently across all study participants? (Yes/No/Unclear)
  ○ Other – Describe
- All study types
  ○ Are baseline characteristics similar between groups? If not, did the analysis control for differences? (Yes/No/Unclear)
  ○ Did the strategy for recruiting participants into the study differ across study groups? (Yes/No/Unclear)
  ○ Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results? (Yes/No/Unclear)
  ○ Did variation from the study protocol compromise the conclusions of the study?
  ○ Was there a high rate of differential or overall attrition? (Yes/No/Unclear)
  ○ Did attrition result in a difference in group characteristics between baseline (or randomization) and follow-up? (Yes/No/Unclear)
  ○ Is the analysis conducted on an intention-to-treat (ITT) basis? (Yes/No/Unclear)
  ○ Were the outcome assessors blinded to the intervention or exposure status of participants? (Yes/No/Unclear)
  ○ Are primary outcomes assessed using valid and reliable measures, implemented consistently across all study participants? (Yes/No/Unclear)
  ○ Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants? (Yes/No/Unclear)
  ○ Are interventions/exposures assessed using valid and reliable measures, implemented consistently across all study participants? (Yes/No/Unclear)
  ○ Were incomplete/missing outcome data adequately reported and the data managed by an accepted method? (Yes/No/Unclear)
  ○ Was the primary outcome pre-specified? Are all pre-specified outcomes reported? (Yes/No/Unclear)
  ○ Was there a substantive conflict of interest which posed a substantive, important threat to validity of the results? (Yes/No/Unclear)
- Overall study rating
- Please assign each study an overall quality rating of “Good,” “Fair,” or “Poor” based on the following definitions. “Fair” is the initial assumption for cohort studies, unless there is significant evidence to prove that it could be categorized as “Good”.
- Quality Rating
  ○ Good
  ○ Fair
  ○ Poor
    ■ If “Fair” or “Poor,” provide rationale for decision.

## VIII KQ 2 Applicability Assessment

- Population (P)
  ○ Study population poorly described
  ○ Inadequate diagnostic evaluation of cough
- Intervention (I)
  ○ Intervention not well described
  ○ Highly selected intervention team or level of training/proficiency not widely available
  ○ Doses not reflected in current practice
  ○ Monitoring practices/visit frequency not in typical practice (e.g., frequent contact, incentives)
  ○ Older versions of an intervention no longer in common use
  ○ Cointerventions likely to modify effectiveness of treatment
- Comparator (C)
  ○ Inadequate comparison therapy
  ○ Comparator(s) not well described
  ○ Use of substandard alternative therapy (e.g., standard of treatment not from current practice)
- Outcomes (O)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Uses lab assessment such as tussigenic challenge as main outcome
  ○ Short-term or surrogate outcomes
- Setting (S)
  ○ Conducted outside of the US and practices not well described or widely divergent relative to US practices
  ○ Not widely accessible technology
- Comments