# Exact Search Strings

## PubMed^®^ search strategy (June 4, 2012)

KQ 1: Instruments used to assess cough

Set # | Terms
#1 | cough[MeSH] OR cough[tiab]
#2 | cough/diagnosis[mesh] OR pain measurement[mesh] OR severity of illness index[mesh] OR questionnaires[mesh] OR rate[tiab] OR rating[tiab] OR rates[tiab] OR rated[tiab] OR assess*[tiab] OR evaluat*[tiab] OR scale[tiab] OR scales[tiab] monitor*[tiab] OR frequency[tiab] OR frequent[tiab] OR score[tiab] OR scores[tiab] OR “visual analog”[tiab] OR “visual analogue”[tiab]OR severity[tiab] OR sound[tiab] OR sounds[tiab] OR register*[tiab] OR measure*[tiab] OR count*[tiab] OR questionnaire[tiab] OR questionnaires[tiab] OR instrument[tiab] OR instruments[tiab]OR (tussigenic[tiab] AND challenge[tiab]) OR “exhaled nitric oxide”[tiab] OR tools[tiab] OR tool[tiab] OR lcq[tiab] OR cqlq[tiab] OR lcm[tiab] OR lifeshirt[tiab] OR lr102[tiab] OR lr100[tiab]
#3 | #1 AND #2
#4 | #3 NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mesh] NOT humans[mesh])
#5 | #4, Limit English

KQ 2: Nonspecific therapies for chronic cough

Set # | Terms
#1 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh])
#2 | Cough[mesh] OR cough[ti]
#3 | #1 AND #2
#4 | #3, Limit to English

## Embase^®^ search strategy (June 4, 2012)

Platform: Embase.com

KQ 1: Instruments used to assess cough

Set # | Terms
#1 | coughing'/de OR cough:ti OR cough:ab
#2 | ‘coughing’/dm_di OR ‘pain assessment’/exp OR ‘questionnaire’/exp OR ‘instrument’/exp OR “severity of illness”:ti OR “severity of illness”:ab OR rate:ti OR rate:ab OR rating:ti OR rating:ab OR rates:ti OR rates:ab OR rated:ti OR rated:ab OR assess*:ti OR assess*:ab OR evaluat*:ti OR evaluat*:ab OR scale:ti OR scale:ab OR scales:ti OR scales:ab OR monitor*:ti OR monitor*:ab OR frequency:ti OR frequency:ab OR frequent:ti OR frequent:ab OR score:ti OR score:ab OR scores:ti OR scores:ab OR “visual analog”:ti OR “visual analog”:ab OR “visual analogue”:ti OR “visual analogue”:ab OR severity:ti OR severity:ab OR sound:ti OR sound:ab OR sounds:ti OR sounds:ab OR register*:ti OR register*:ab OR measure*:ti OR measure*:ab OR count*:ti OR count*:ab OR questionnaire:ti OR questionnaire:ab OR questionnaires:ti OR questionnaires:ab OR instrument:ti OR instrument:ab OR instruments:ti OR instruments:ab OR (tussigenic:ti AND challenge:ti) OR (tussigenic:ab AND challenge:ab) OR “exhaled nitric oxide”:ti OR “exhaled nitric oxide”:ab OR tools:ti OR tools:ab OR tool:ti OR tool:ab OR lcq:ti OR lcq:ab OR cqlq:ti OR cqlq:ab OR lcm:ti OR lcm:ab OR lifeshirt:ti OR lifeshirt:ab OR lr102:ti OR lr102:ab OR lr100:ti OR lr100:ab
#3 | #1 AND #2
#4 | #3 NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #4 AND ([embase]/lim NOT [medline]/lim)
#6 | #5, Limits: Human, English

KQ 2: Nonspecific therapies for chronic cough

Set # | Terms
#1 | ‘coughing’/de OR cough:ti
#2 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* OR ‘clinical study’/exp OR “clinical trial”:ti OR “clinical trial”:ab OR “clinical trials”:ti OR “clinical trials”:ab OR ‘evaluation’/exp OR “evaluation study”:ti OR “evaluation study”:ti OR “evaluation studies”:ti OR “evaluation studies”:ab OR “intervention study”:ti OR “intervention study”:ab OR “intervention studies”:ti OR “intervention studies”:ab OR “case control”:ti OR “case control”:ab OR ‘cohort analysis’/exp OR cohort:ti OR cohort:ab OR longitudinal*:ti OR longitudinal*:ab OR prospective:ti OR prospective:ab OR prospectively:ti OR prospectively:ab OR retrospective:ti OR retrospective:ab OR ‘follow up’/exp OR “follow up”:ti OR “follow up”:ab OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ti OR “comparative study”:ab OR “comparative studies”:ti OR “comparative studies”:ab OR ‘evidence based medicine’/exp OR “systematic review”:ti OR “systematic review”:ab OR “meta-analysis”:ti OR “meta-analysis”:ab OR “meta-analyses”:ti OR “meta-analyses”:ab
#3 | #1 AND #2
#4 | #3 NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #4 AND [embase]/lim NOT [medline]/lim
#6 | #5, Limits: Human, English

## Cochrane search strategy (June 4, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

KQ 1: Instruments used to assess cough

Set # | Terms
#1 | MeSH descriptor Cough explode all trees OR cough:ti,ab
#2 | MeSH descriptor Cough explode all trees with qualifier: DI OR MeSH descriptor Pain Measurement explode all trees OR MeSH descriptor Severity of Illness Index explode all trees OR MeSH descriptor Questionnaires explode all trees OR rate:ti,ab OR rating:ti,ab OR rates:ti,ab OR rated:ti,ab OR assess*:ti,ab OR evaluat*:ti,ab OR scale:ti,ab OR scales:ti,ab OR monitor*:ti,ab OR frequency:ti,ab OR frequent:ti,ab OR score:ti,ab OR scores:ti,ab OR “visual analog”:ti,ab OR “visual analogue”:ti,ab OR severity:ti,ab OR sound:ti,ab OR sounds:ti,ab OR register*:ti,ab OR measure*:ti,ab OR count*:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR instrument:ti,ab OR instruments:ti,ab OR (tussigenic:ti,ab AND challenge:ti,ab) OR “exhaled nitric oxide”:ti,ab OR tools:ti,ab OR tool:ti,ab OR lcq:ti,ab OR cqlq:ti,ab OR lcm:ti,ab OR lifeshirt:ti,ab OR lr102:ti,ab OR lr100:ti,ab
#3 | #1 AND #2
#4 | #3 in Clinical Trials, Systematic Reviews

KQ 2: Nonspecific therapies for chronic cough

Set # | Terms
#1 | MeSH descriptor Cough explode all trees OR cough:ti
#2 | Limit #1 to Clinical Trials, Systematic Reviews

## Grey Literature Searches

### ClinicalTrials.gov (July 18, 2012)

Terms: Cough (as condition)

### WHO: International Clinical Trials Registry Platform Search Portal (July 18, 2012)

Terms: Cough (in title)

ProQuest COS Conference Papers Index (January 18, 2012)

Set # | Terms
#1 | cough[su] OR cough[all]
#2 | Limit to 2010-