# Acronyms and Abbreviations

ABSS: Acute Bronchitis Severity Score
ACCP: American College of Chest Physicians
ACE: angiotensin-converting enzyme
ACOS: Adverse Cough Outcome Survey
AHRQ: Agency for Healthcare Research and Quality
BPC: bronchoprovocation challenge
CASA-Q: Cough and Sputum Assessment Questionnaire
CBSAS: Chronic Bronchitis Symptoms Assessment Scale
CCIQ: Chronic Cough Impact Questionnaire
CDSR: Cochrane Database of Systematic Reviews
CER: comparative effectiveness review
CES-D: Center for Epidemiologic Studies Depression Scale
CI: confidence interval
COPD: chronic obstructive pulmonary disease
CQLQ: Cough-specific Quality of Life Questionnaire
CSD: Cough Severity Diary
EuroQol: European Quality of Life questionnaire
FDA: U.S. Food and Drug Administration
FET: forced expiratory technique
FEV1: forced expiratory volume in 1 second
FVC: forced vital capacity
GERD: gastroesophageal reflux disease
GRC: Global Rating of Change
HADS: Hospital Anxiety and Depression Scale
HRQOL: health-related quality of life
KQ: Key Question
LCCQ: Lung Cancer Cough Questionnaire
LCQ: Leicester Cough Questionnaire
MSFSD: Modified Symptom Frequency/Symptom Distress scale
NAEB: nonasthmatic eosinophilic bronchitis
NPV: negative predictive value
PCQ: Pediatric Cough Questionnaire
PC-QOL: Parent Cough-specific Quality-of-Life questionnaire
PEP: positive expiratory pressure
PICOTS: population, interventions, comparators, outcomes, timing of outcomes, and settings
PPV: positive predictive value
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QLTP: Questionnaire for Lung Transplant Patients
QUADAS-2: QUality Assessment tool for Diagnostic Accuracy Studies-2
RCT: randomized controlled trial
SF-36: Medical Outcomes Study 36-Item Short Form Health Survey
SGRQ: St. George's Respiratory Questionnaire
SIP: Sickness Impact Profile
TEP: Technical Expert Panel
UACS: upper airway cough syndrome
VCD: verbal category descriptive scale
WHO: World Health Organization