# References

1 Burt VL, Whelton P, Roccella EJ, et al. Prevalence of hypertension in the US adult population. Results from the Third National Health and Nutrition Examination Survey, 1988–1991. Hypertension. 1995;25(3):305-13. [pmid: 7875754].
2 World Health Organization. World health report 2002: reducing risks, promoting healthy life. World Health Organization. Geneva, Switzerland. Available at: www.who.int/whr/2002. December 14, 2006.
3 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report.[erratum appears in JAMA. 2003 Jul 9;290(2):197]. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
4 Chou R, Helfand M, Carson S. Drug Class Review on Angiotensin Converting Enzyme Inhibitors. Final Report. 2005. June. Available at: www.ohsu.edu/drugeffectiveness/reports/final.cfm. 17 August 2006.
5 Furmaga E, Glassman P, Rhodes S, et al. Drug Class Review on Angiotensin II Receptor Antagonists. Final Report. 2006. February. Available at: www.ohsu.edu/drugeffectiveness/reports/final.cfm. 17 August 2006.
6 Israili ZH, Hall WD. Cough and angioneurotic edema associated with angiotensin-converting enzyme inhibitor therapy. A review of the literature and pathophysiology. Ann Intern Med. 1992;117(3):234-42. [pmid: 1616218].
7 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
8 Anonymous. Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews. York, UK. NHS Centre for Reviews and Dissemination. 2001. Mar. Report No.: CRD Report No. 4 (2nd edition).
9 Rothwell PM. External validity of randomised controlled trials: "to whom do the results of this trial apply?". Lancet. 2005;365(9453):82-93. [pmid: 15639683].
10 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
11 Derosa G, Cicero AF, Ciccarelli L, et al. A randomized, double-blind, controlled, parallel-group comparison of perindopril and candesartan in hypertensive patients with type 2 diabetes mellitus. Clin Ther. 2003;25(7):2006-21. [pmid: 12946547].
12 Schram MT, van Ittersum FJ, Spoelstra-de Man A, et al. Aggressive antihypertensive therapy based on hydrochlorothiazide, candesartan or lisinopril as initial choice in hypertensive type II diabetic individuals: effects on albumin excretion, endothelial function and inflammation in a double-blind, randomized clinical trial.[see comment]. J Hum Hypertens. 2005;19(6):429-37. [pmid: 15647778].
13 Ruilope L, Jager B, Prichard B. Eprosartan versus enalapril in elderly patients with hypertension: a double-blind, randomized trial. Blood Press. 2001;10(4):223-9. [pmid: 11800061].
14 Malacco E, Santonastaso M, Vari NA, et al. Comparison of valsartan 160 mg with lisinopril 20 mg, given as monotherapy or in combination with a diuretic, for the treatment of hypertension: the Blood Pressure Reduction and Tolerability of Valsartan in Comparison with Lisinopril (PREVAIL) study.[erratum appears in Clin Ther. 2004 Jul;26(7):1185]. Clin Ther. 2004;26(6):855-65. [pmid: 15262456].
15 Ruff D, Gazdick LP, Berman R, et al. Comparative effects of combination drug therapy regimens commencing with either losartan potassium, an angiotensin II receptor antagonist, or enalapril maleate for the treatment of severe hypertension. J Hypertens. 1996;14(2):263-70. [pmid: 8728306].
16 Saito S, Asayama K, Ohkubo T, et al. The second progress report on the Hypertension Objective treatment based on Measurement by Electrical Devices of Blood Pressure (HOMED-BP) study. Blood Press Monit. 2004;9(5):243-7. [pmid: 15472496].
17 Rosei EA, Rizzoni D, Muiesan ML, et al. Effects of candesartan cilexetil and enalapril on inflammatory markers of atherosclerosis in hypertensive patients with non-insulin-dependent diabetes mellitus. J Hypertens. 2005;23(2):435-44. [pmid: 15662233].
18 Uchiyama-Tanaka Y, Mori Y, Kishimoto N, et al. Comparison of the effects of quinapril and losartan on carotid artery intima-media thickness in patients with mild-to-moderate arterial hypertension. Kidney & Blood Pressure Research. 2005;28(2):111-6. [pmid: 15741734].
19 Hasford J, Mimran A, Simons WR. A population-based European cohort study of persistence in newly diagnosed hypertensive patients. J Hum Hypertens. 2002;16(8):569-75. [pmid: 12149663].
20 Robles NR, Angulo E, Grois J, et al. Comparative effects of fosinopril and irbesartan on hematopoiesis in essential hypertensives. Ren Fail. 2004;26(4):399-404. [pmid: 15462108].
21 Mogensen CE, Neldam S, Tikkanen I, et al. Randomised controlled trial of dual blockade of renin-angiotensin system in patients with hypertension, microalbuminuria, and non-insulin dependent diabetes: the candesartan and lisinopril microalbuminuria (CALM) study.[see comment]. BMJ. 2000;321(7274):1440-4. [pmid: 11110735].
22 Rabbia F, Silke B, Carra R, et al. Heart rate variability and baroreflex sensitivity during fosinopril, irbesartan and atenolol therapy in hypertension. Clinical Drug Investigation. 2004;24(11):651-9. [pmid: 17523728].
23 Lacourciere Y, Belanger A, Godin C, et al. Long-term comparison of losartan and enalapril on kidney function in hypertensive type 2 diabetics with early nephropathy. Kidney Int. 2000;58(2):762-9. [pmid: 10916100].
24 Lacourciere Y, Neutel JM, Davidai G, et al. A multicenter, 14-week study of telmisartan and ramipril in patients with mild-to-moderate hypertension using ambulatory blood pressure monitoring. Am J Hypertens. 2006;19(1):104-12. [pmid: 16461201].
25 Williams B, Gosse P, Lowe L, et al. The prospective, randomized investigation of the safety and efficacy of telmisartan versus ramipril using ambulatory blood pressure monitoring (PRISMA I). J Hypertens. 2006;24(1):193-200. [pmid: 16331118].
26 Fogari R, Zoppi A, Preti P, et al. Differential effects of ACE-inhibition and angiotensin II antagonism on fibrinolysis and insulin sensitivity in hypertensive postmenopausal women. Am J Hypertens. 2001;14(9 Pt 1):921-6. [pmid: 11587159].
27 Elliott WJ. Double-blind comparison of eprosartan and enalapril on cough and blood pressure in unselected hypertensive patients. Eprosartan Study Group. J Hum Hypertens. 1999;13(6):413-7. [pmid: 10408592].
28 Argenziano L, Trimarco B. Effect of eprosartan and enalapril in the treatment of elderly hypertensive patients: subgroup analysis of a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):9-14. [pmid: 10216806].
29 Gavras I, Gavras H. Effects of eprosartan versus enalapril in hypertensive patients on the renin-angiotensin-aldosterone system and safety parameters: results from a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):15-24. [pmid: 10216807].
30 Levine B. Effect of eprosartan and enalapril in the treatment of black hypertensive patients: subgroup analysis of a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):25-32. [pmid: 10216808].
31 Breeze E, Rake EC, Donoghue MD, et al. Comparison of quality of life and cough on eprosartan and enalapril in people with moderate hypertension. J Hum Hypertens. 2001;15(12):857-62. [pmid: 11773988].
32 Neutel JM, Frishman WH, Oparil S, et al. Comparison of telmisartan with lisinopril in patients with mild-to-moderate hypertension. Am J Ther. 1999;6(3):161-6. [pmid: 10423659].
33 Fogari R, Mugellini A, Zoppi A, et al. Effects of valsartan compared with enalapril on blood pressure and cognitive function in elderly patients with essential hypertension. Eur J Clin Pharmacol. 2004;59(12):863-8. [pmid: 14747881].
34 Black HR, Graff A, Shute D, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy, tolerability and safety compared to an angiotensin-converting enzyme inhibitor, lisinopril. J Hum Hypertens. 1997;11(8):483-9. [pmid: 9322828].
35 Townsend R, Haggert B, Liss C, et al. Efficacy and tolerability of losartan versus enalapril alone or in combination with hydrochlorothiazide in patients with essential hypertension. Clin Ther. 1995;17(5):911-23. [pmid: 8595643].
36 Mimran A, Ruilope L, Kerwin L, et al. A randomised, double-blind comparison of the angiotensin II receptor antagonist, irbesartan, with the full dose range of enalapril for the treatment of mild-to-moderate hypertension. J Hum Hypertens. 1998;12(3):203-8. [pmid: 9579771].
37 Cuspidi C, Muiesan ML, Valagussa L, et al. Comparative effects of candesartan and enalapril on left ventricular hypertrophy in patients with essential hypertension: the candesartan assessment in the treatment of cardiac hypertrophy (CATCH) study. J Hypertens. 2002;20(11):2293-300. [pmid: 12409969].
38 Coca A, Calvo C, Garcia-Puig J, et al. A multicenter, randomized, double-blind comparison of the efficacy and safety of irbesartan and enalapril in adults with mild to moderate essential hypertension, as assessed by ambulatory blood pressure monitoring: the MAPAVEL Study (Monitorizacion Ambulatoria Presion Arterial APROVEL). Clin Ther. 2002;24(1):126-38. [pmid: 11833827].
39 Karlberg BE, Lins LE, Hermansson K. Efficacy and safety of telmisartan, a selective AT1 receptor antagonist, compared with enalapril in elderly patients with primary hypertension. TEES Study Group. J Hypertens. 1999;17(2):293-302. [pmid: 10067800].
40 Fogari R, Mugellini A, Zoppi A, et al. Losartan and perindopril effects on plasma plasminogen activator inhibitor-1 and fibrinogen in hypertensive type 2 diabetic patients. Am J Hypertens. 2002;15(4 Pt 1):316-20. [pmid: 11991216].
41 McInnes GT, O'Kane KP, Istad H, et al. Comparison of the AT1-receptor blocker, candesartan cilexetil, and the ACE inhibitor, lisinopril, in fixed combination with low dose hydrochlorothiazide in hypertensive patients. J Hum Hypertens. 2000;14(4):263-9. [pmid: 10805052].
42 Amerena J, Pappas S, Ouellet JP, et al. ABPM comparison of the anti-hypertensive profiles of telmisartan and enalapril in patients with mild-to-moderate essential hypertension. J Int Med Res. 2002;30(6):543-52. [pmid: 12526280].
43 De Rosa ML, Cardace P, Rossi M, et al. Comparative effects of chronic ACE inhibition and AT1 receptor blocked losartan on cardiac hypertrophy and renal function in hypertensive patients. J Hum Hypertens. 2002;16(2):133-40. [pmid: 11850771].
44 Naidoo DP, Sareli P, Marin F, et al. Increased efficacy and tolerability with losartan plus hydrochlorothiazide in patients with uncontrolled hypertension and therapy-related symptoms receiving two monotherapies. Adv Ther. 1999;16(5):187-99. [pmid: 10915394].
45 Tikkanen I, Omvik P, Jensen HA. Comparison of the angiotensin II antagonist losartan with the angiotensin converting enzyme inhibitor enalapril in patients with essential hypertension. J Hypertens. 1995;13(11):1343-51. [pmid: 8984133].
46 Nielsen S, Dollerup J, Nielsen B, et al. Losartan reduces albuminuria in patients with essential hypertension. An enalapril controlled 3 months study. Nephrol Dial Transplant. 1997;12(Suppl 2):19-23. [pmid: 9269694].
47 Mallion JM, Bradstreet DC, Makris L, et al. Antihypertensive efficacy and tolerability of once daily losartan potassium compared with captopril in patients with mild to moderate essential hypertension. J Hypertens Suppl. 1995;13(1):S35-S41.
48 Roca-Cusachs A, Oigman W, Lepe L, et al. A randomized, double-blind comparison of the antihypertensive efficacy and safety of once-daily losartan compared to twice-daily captopril in mild to moderate essential hypertension. Acta Cardiol. 1997;52(6):495-506. [pmid: 9542575].
49 Larochelle P, Flack JM, Marbury TC, et al. Effects and tolerability of irbesartan versus enalapril in patients with severe hypertension. Irbesartan Multicenter Investigators. Am J Cardiol. 1997;80(12):1613-5. [pmid: 9416950].
50 Malmqvist K, Kahan T, Dahl M. Angiotensin II type 1 (AT1) receptor blockade in hypertensive women: benefits of candesartan cilexetil versus enalapril or hydrochlorothiazide. Am J Hypertens. 2000;13(5 Pt 1):504-11. [pmid: 10826401].
51 Shibasaki Y, Masaki H, Nishiue T, et al. Angiotensin II type 1 receptor antagonist, losartan, causes regression of left ventricular hypertrophy in end-stage renal disease. Nephron. 2002;90(3):256-61. [pmid: 11867945].
52 Barnett AH, Bain SC, Bouter P, et al. Angiotensin-receptor blockade versus converting-enzyme inhibition in type 2 diabetes and nephropathy. [erratum appears in N Engl J Med. 2005 Apr 21;352(16)1731]. N Engl J Med. 2004;351(19):1952-61. [pmid: 15516696].
53 Schieffer B, Bunte C, Witte J, et al. Comparative effects of AT1-antagonism and angiotensin-converting enzyme inhibition on markers of inflammation and platelet aggregation in patients with coronary artery disease. J Am Coll Cardiol. 2004;44(2):362-8. [pmid: 15261932].
54 Eguchi K, Kario K, Shimada K. Comparison of candesartan with lisinopril on ambulatory blood pressure and morning surge in patients with systemic hypertension. Am J Cardiol. 2003;92(5):621-4. [pmid: 12943892].
55 Matsuda H, Hayashi K, Saruta T. Distinct time courses of renal protective action of angiotensin receptor antagonists and ACE inhibitors in chronic renal disease. J Hum Hypertens. 2003;17(4):271-6. [pmid: 12692572].
56 Rajzer M, Klocek M, Kawecka-Jaszcz K. Effect of amlodipine, quinapril, and losartan on pulse wave velocity and plasma collagen markers in patients with mild-to-moderate arterial hypertension. Am J Hypertens. 2003;16(6):439-44. [pmid: 12799091].
57 Koylan N, Acarturk E, Canberk A, et al. Effect of irbesartan monotherapy compared with ACE inhibitors and calcium-channel blockers on patient compliance in essential hypertension patients: a multicenter, open-labeled, three-armed study. Blood Press Suppl. 2005;1:23-31. [pmid: 16060413].
58 Celik T, Iyisoy A, Kursaklioglu H, et al. The comparative effects of telmisartan and ramipril on P-wave dispersion in hypertensive patients: a randomized clinical study. Clin Cardiol. 2005;28(6):298-302. [pmid: 16028466].
59 Ragot S, Ezzaher A, Meunier A, et al. Comparison of trough effect of telmisartan vs perindopril using self blood pressure measurement: EVERESTE study. J Hum Hypertens. 2002;16(12):865-73. [pmid: 12522468].
60 Kavgaci H, Sahin A, Onder Ersoz H, et al. The effects of losartan and fosinopril in hypertensive type 2 diabetic patients. Diabetes Research & Clinical Practice. 2002;58(1):19-25. [pmid: 12161053].
61 Shand BI. Haemorheological effects of losartan and enalapril in patients with renal parenchymal disease and hypertension.[see comment]. J Hum Hypertens. 2000;14(5):305-9. [pmid: 10822316].
62 Shand BI, Lynn KL. A comparative study of losartan and enalapril on erythropoiesis and renal function in hypertensive patients with renal parenchymal disease. Clin Nephrol. 2000;54(5):427-8. [pmid: 11105808].
63 Verdecchia P, Schillaci G, Reboldi GP, et al. Long-term effects of losartan and enalapril, alone or with a diuretic, on ambulatory blood pressure and cardiac performance in hypertension: a case-control study. Blood Press Monit. 2000;5(3):187-93. [pmid: 10915233].
64 Ghiadoni L, Magagna A, Versari D, et al. Different effect of antihypertensive drugs on conduit artery endothelial function. Hypertension. 2003;41(6):1281-6. [pmid: 12719441].
65 Avanza AC Jr, El Aouar LM, Mill JG. Reduction in left ventricular hypertrophy in hypertensive patients treated with enalapril, losartan or the combination of enalapril and losartan. Arquivos Brasileiros de Cardiologia. 2000;74(2):103-17. [pmid: 10904284].
66 Franke H. Antihypertensive effects of candesartan cilexetil, enalapril and placebo. J Hum Hypertens. 1997;11(Suppl 2):S61-2. [pmid: 9331010].
67 Mazzaglia G, Mantovani LG, Sturkenboom MC, et al. Patterns of persistence with antihypertensive medications in newly diagnosed hypertensive patients in Italy: a retrospective cohort study in primary care. J Hypertens. 2005;23(11):2093-100. [pmid: 16208153].
68 Sato A, Tabata M, Hayashi K, et al. Effects of the angiotensin II type 1 receptor antagonist candesartan, compared with angiotensin-converting enzyme inhibitors, on the urinary excretion of albumin and type IV collagen in patients with diabetic nephropathy. Clin Exp Nephrol. 2003;7(3):215-20. [pmid: 14586718].
69 Gregoire JP, Moisan J, Guibert R, et al. Tolerability of antihypertensive drugs in a community-based setting. Clin Ther. 2001;23(5):715-26. [pmid: 11394730].
70 Mackay FJ, Pearce GL, Mann RD. Cough and angiotensin II receptor antagonists: cause or confounding?. Br J Clin Pharmacol. 1999;47(1):111-4. [pmid: 10073748].
71 Bloom BS. Continuation of initial antihypertensive medication after 1 year of therapy. Clin Ther. 1998;20(4):671-81. [pmid: 9737827].
72 Bourgault C, Senecal M, Brisson M, et al. Persistence and discontinuation patterns of antihypertensive therapy among newly treated patients: a population-based study. J Hum Hypertens. 2005;19(8):607-13. [pmid: 15920457].
73 Conlin PR, Gerth WC, Fox J, et al. Four-year persistence patterns among patients initiating therapy with the angiotensin II receptor antagonist losartan versus other artihypertensive drug classes. Clin Ther. 2001;23(12):1999-2010. [pmid: 11813934].
74 Degli Esposti L, Degli Esposti E, Valpiani G, et al. A retrospective, population-based analysis of persistence with antihypertensive drug therapy in primary care practice in Italy. Clin Ther. 2002;24(8):1347-57. discussion 1346. [pmid: 12240784].
75 Degli Esposti E, Sturani A, Di Martino M, et al. Long-term persistence with antihypertensive drugs in new patients. J Hum Hypertens. 2002;16(6):439-44. [pmid: 12037702].
76 Erkens JA, Panneman MM, Klungel OH, et al. Differences in antihypertensive drug persistence associated with drug class and gender: a PHARMO study. Pharmacoepidemiology & Drug Safety. 2005;14(11):795-803. [pmid: 16178043].
77 Marentette MA, Gerth WC, Billings DK, et al. Antihypertensive persistence and drug class. Can J Cardiol. 2002;18(6):649-56. [pmid: 12107422].
78 Wogen J, Kreilick CA, Livornese RC, et al. Patient adherence with amlodipine, lisinopril, or valsartan therapy in a usual-care setting.[see comment]. Journal of Managed Care Pharmacy. 2003;9(5):424-9. [pmid: 14613440].
79 Burke TA, Sturkenboom MC, Lu SE, et al. Discontinuation of antihypertensive drugs among newly diagnosed hypertensive patients in UK general practice.[see comment]. J Hypertens. 2006;24(6):1193-200. [pmid: 16685222].