# Abbreviations

ACE: Angiotensin-converting enzyme
ACEI(s): Angiotensin-converting enzyme inhibitor(s)
AHRQ: Agency for Healthcare Research and Quality
ARB(s): Angiotensin II receptor blocker(s)/antagonist(s)
AT _1 _: Angiotensin specific receptor
CER: Comparative Effectiveness Review
DBP: Diastolic blood pressure
EF: Ejection fraction
EPC: Evidence-based Practice Centers
ESRD: End-stage renal disease
GFR: Glomerular filtration rate
HgbA1c: Glycated hemoglobin
HCTZ: Hydrochlorothiazide
HDL: High-density lipoprotein
LDL: Low-density lipoprotein
LV: Left ventricular
LVEF: Left ventricular ejection fraction
LVH: Left ventricular hypertrophy
LVMI: Left ventricular mass index
MeSH: Medical Subject Headings
MI: Myocardial infarction
RCT: Randomized controlled trial
SBP: Systolic blood pressure
SD: Standard deviation
SF-36: Medical Outcomes Study 36-Item Short Form Health Survey
SRC: Scientific Resource Center
TC: Total cholesterol
TG: Triglyceride
UAE: Urinary albumin excretion
USPSTF: U.S. Preventive Services Task Force