# Acknowledgments

The authors gratefully acknowledge Kathryn E. Cline, who managed the project in its early stages, and R. Julian Irvine, who provided assistance with editing and project management.

AHRQ Contacts

- Beth A. Collins-Sharp, R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Artyom Sedrakyan, M.D., Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD