# Future Research

With the exception of rates of cough, the hypothesis that ACEIs and ARBs have clinically meaningful differences in long-term outcomes in individuals with essential hypertension is not strongly supported by the available evidence. Given the importance of these issues, it is notable how few large, long-term, head-to-head studies have been published. Further research in this area should consider:

- Subgroups of special importance such as individuals essential hypertension and diabetes mellitus, congestive heart failure, chronic kidney disease, and dyslipidemia.
- Pragmatic designs such as clinical trials in which treatment is consistent with typical clinical practice, or randomization by organizationally meaningful clusters, such as practice organizations or health plans.
- Outcomes over several years.
- Outcomes measured according to current clinical standards.
- Broader representation of groups such as the elderly and ethnic and racial minorities.
- Evaluation of specific pairs of ACEIs and ARBs to allow differentiation within class.

Given the demonstrated higher incidence of cough with ACEIs, it would also be valuable to gain more precise understanding of the impact of cough on quality of life, care patterns (e.g., use of therapeutic agents for cough symptoms or conditions associated with cough), and health outcomes, particularly for individuals who continue to use ACEIs.