# Summary and Discussion

A succinct summary of the results of this review of the comparative long-term benefits and harms of ACEIs versus ARBs for adults with essential hypertension is provided in three tables. First, we give an aggregated view of the strength of evidence and brief conclusions (Table 11). Second, we describe the nature and quality of the evidence in a format recommended by the GRADE Committee (Table 12). Finally, we summarize the quantitative analyses of outcomes, offering an estimate of the comparative outcomes for ACES (Table 13).

Table 11

Summary of evidence on comparative long-term benefits and harms of ACEIs vs. ARBs for essential hypertension

Key question | Strength of evidence | Conclusions
Key Question 1. For adult patients with essential hypertension, how do ACEIs and ARBs differ in the following health outcomes:
a. Blood pressure control? | High | ACEIs and ARBs appear to have similar long-term effects on blood pressure among individuals with essential hypertension. This conclusion is based on evidence from 50 studies (47 RCTs, one nonrandomized controlled clinical trial, one retrospective cohort study, and one case-control study) in which 13,532 patients receiving an ACEI or an ARB were followed for periods from 12 weeks to 5 years (median 16.5 weeks). Blood pressure outcomes were confounded by additional treatments and varying dose escalation protocols.
b. Mortality and major cardiovascular events? | Moderate | Due to insufficient numbers of deaths or major cardiovascular events in the included studies, it was not possible to discern any differential effect of ACEIs versus ARBs for these critical outcomes. In nine studies that reported mortality, MI, or clinical stroke as outcomes among 3356 subjects, there were 16 deaths and 13 strokes reported. This may reflect low event rates among otherwise healthy patients and relatively few studies with extended followup.
c. Quality of life? | Low | No differences were found in measures of general quality of life; this is based on four studies, two of which did not provide quantitative data.
d. Rate of use of a single antihypertensive? | High | There was no statistically evident difference in the rate of treatment success based on use of a single antihypertensive for ARBs compared to ACEIs. The trend toward less frequent addition of a second agent to an ARB was heavily influenced by retrospective cohort studies, where medication discontinuation rates were higher in ACEI-treated patients, and by RCTs with very loosely defined protocols for medication titration and switching.
e. Risk factor reduction and other intermediate outcomes? | Moderate (lipid levels, markers of carbohydrate metabolism/diabetes control, progression of renal disease) to Low (progression to type 2 diabetes and LV mass/function) | There were no consistent differential effects of ACEIs versus ARBs on several potentially important clinical outcomes, including lipid levels, progression to type 2 diabetes mellitus, markers of carbohydrate metabolism/diabetes control, measures of LV mass or function, and progression of renal disease (either based on creatinine, GFR, or proteinuria). Relatively few studies assessed these outcomes over the long term.
Key Question 2. For adult patients with essential hypertension, how do ACEIs and ARBs differ in safety, adverse events, tolerability, persistence, and adherence? | High (cough, withdrawals due to adverse events) to Moderate (persistence/adherence) to Low (angioedema) | ACEIs have been consistently shown to be associated with greater risk of cough than ARBs (pooled odds ratio [Peto] = 0.32). For RCTs, this translates to a difference in rates of cough of 6.7 percent (NNT = 15); however, for cohort studies with lower rates of cough, this translates to a difference of 1.1 percent (NNT = 87). This is generally consistent with evidence reviewed regarding withdrawals due to adverse events, in which the NNT is on the order of 27 – that is, one more withdrawal per 27 patients treated with an ACEI versus an ARB. There was no evidence of differences in rates of other commonly reported specific adverse events. Angioedema was reported only in patients treated with ACEIs; however, because angioedema was rarely explicitly reported in the included studies, it was not possible to estimate its frequency in this population. ACEIs and ARBs have similar rates of adherence based on pill counts; this result may not be applicable outside the clinical trial setting. Rates of continuation with therapy appear to be somewhat better with ARBs than with ACEIs; however, due to variability in definitions, limitations inherent in longitudinal cohort studies, and relatively small sample sizes for ARBs, the precise magnitude of this effect is difficult to quantify.
Key Question 3. Are there subgroups of patients based on demographic characteristics (age, racial and ethnic groups, sex), use of other medications concurrently, or comorbidities for which ACEIs or ARBs are more effective, associated with fewer adverse events, or better tolerated? | Very low | Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACEIs and ARBs for any particular patient subgroup.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); GFR = glomerular filtration rate; LV = left ventricular; MI = myocardial infarction; NNT = number-needed-to-treat; RCT(s) = randomized controlled trial(s)

Table 12

GRADE summary table

Studies | Design | Quality | Consistency | Directness | SD | SA | PB | DR | PC
Outcome: Blood pressure control
50 | RCTs (1 nonrandomized controlled trial, 1 cohort study, 1 case-control) | Confounded by additional treatments, dose escalation | Consistent results | Direct | − | − | − | − | −
Outcome: Mortality and major cardiovascular events
9 | RCTs | No serious limitations | Consistent results | Direct | + | − | − | − | −
Outcome: Morbidity/quality of life
4 | RCTs | No serious limitations | Consistent results | Direct | − | − | − | − | −
Outcome: Safety (serious and overall adverse events, withdrawals due to adverse events)
7 – serious AEs 29 – overall AEs 24 – withdrawals due to AEs | RCTs (1 nonrandomized controlled trial; 1 case-control) | Variation in study protocols and data reporting | Consistent results | Direct | − | − | − | − | −
Outcome: Specific adverse events
30 | RCTs (3 cohort studies) | Variation in data reporting | Consistent results | Direct | − | − | − | − | −
Outcome: Persistence/adherence
17 | RCTs (9 cohort studies) | Variation in data reporting | Consistent results | Direct | − | − | − | − | −
Outcome: Rate of use of a single agent for blood pressure control
22 | RCTs (2 cohort studies, 1 case-control) | No serious flaws | Consistent results | Direct | − | − | − | − | −
Outcome: Lipid levels
12 | RCTs (1 case- control) | No serious flaws | Inconsistent results between studies and between lipid parameters | Direct | − | − | − | − | −
Outcome: Rates of progression to type 2 diabetes
0 | NA | NA | NA | NA | + | − | − | − | −
Outcome: Markers of carbohydrate metabolism/diabetes control
13 | RCTs (1 nonrandomized controlled trial, 1 case-control) | No serious flaws | Inconsistent results between head-to-head studies and placebo- controlled studies | Direct | − | − | − | − | −
Outcome: Measures of LV mass/function
8 | RCTs (1 nonrandomized controlled trial; 1 case-control) | Poor quality studies; small sample sizes | Consistent results | Direct | − | − | − | − | −
Outcome: Measures of kidney disease
15 GFR | RCTs (1 nonrandomized controlled trial, 1 cohort study, 1 case-control) | Poor quality studies; different parameters measured | Consistent results | Direct | − | − | − | − | −
10 proteinuria | RCTs (1 nonrandomized controlled trial, 1 cohort study, 1 case-control) | Poor quality studies; different parameters measured | Inconsistent results | Direct | − | − | − | − | −

Abbreviations: AE(s) = adverse event(s); DR = dose response; LV = left ventricular; PB = publication bias; PC = all plausible confounders would reduce the effect; RCT(s) = randomized controlled trial(s); SA = strong association (+ = very strong, ++ = extremely strong); SD = sparse data

Table 13

GRADE balance sheet

Outcome | Number of patients | | Effect based on pooling | | Quality | Relative importance
Outcome | ACEI | ARB | Effect (95% CI) | NNT | Quality | Relative importance
BP reduction | ~ 6700 | ~ 6700 | - | - | High | Critical
Rate of use of a single antihypertensive for BP control | 2668/7296 (37%) | 2268/4714 (48%) | Risk difference 1.3% (−1.0 to 3.5%) | - | High
Mortality and major CV events | 1663 | 1659 | - | - | Moderate | Critical
Morbidity/QoL | ~ 550 | ~ 550 | No difference detected | - | Low | -
Cough | 1091/42,029 (2.6%) | 203/19,949 (1%) | Peto odds ratio 0.32 (0.29 to 0.36) | 15 to 87^*^ | High
Adverse events – withdrawals | 216/3593 (6.0%) | 126/4071 (3.1%) | Peto odds ratio 0.51 (0.38 to 0.70) | 27 | High | Critical
Persistence/adherence | ~ 95% of ~ 1400 (pill count) ~ 30% to 60% of ~ 108,000 (continuation) | ~ 95% of ~ 1500 (pill count) ~ 33% to 64% of ~ 40,100 (continuation) | - | - | Moderate
Lipid levels | 870 | 807 | - | - | Moderate | -
Progression to type 2 diabetes | No data | No data | - | - | Low | -
Markers of carbohydrate metabolism/diabetes control | 807 | 741 | - | - | Moderate | -
Measures of LV mass/function | 386 | 306 | - | - | Low | -
Measures of kidney disease – creatinine/GFR | 329 | 262 | Effect size (SMD) 0.02 (−0.19 to 0.23) | - | Moderate | -
Measures of kidney disease – proteinuria | 117 | 114 | Effect size (SMD) −0.42 (−0.97 to 0.14) | - | Moderate | -

* The observed rates of cough appear much higher in RCTs than cohort studies; this is due to the higher detection when the patient is queried systematically for this symptom. Thus, based on the overall odds ratio of 0.32, when we use the rate of cough with ACEIs equal to the RCTs (9.9 percent) the absolute rate difference is estimated to be 6.7 percent (NNT = 15); however, when we use the rate of cough with ACEIs equal to the cohort studies (1.7 percent) the absolute rate difference is estimated to be 1.1 percent (NNT = 87). The latter estimate is likely to be more clinically relevant.

Abbreviations: BP = blood pressure; CI = confidence interval; CV = cardiovascular; GFR = glomerular filtration rate; LV = left ventricular; NNT = number-needed-to-treat; QoL = quality of life; SMD = standardized mean difference