# Results

## Literature Search and Screening

Our searches of the literature identified a total of 1,185 citations. Table 2 details the number of citations identified from each source.

Table 2

Sources of citations

Source | Number of citations
MEDLINE^®^ | 1078
Cochrane Central Register of Controlled Trials | 45
Register of systematic reviews underway in the Cochrane Hypertension Group | 0
References of review articles and primary studies | 23
Scientific information packets submitted by pharmaceutical companies | 17
Other (recommendations from staff at AHRQ or SRC or from project investigators) | 22
Total: | 1185

Figure 1 describes the flow of literature through the screening process. Four hundred and twenty-three (423) citations were excluded at the abstract screening stage. Of the 762 citations that passed the abstract screening, 165 were review or methods articles, 136 were studies of ACEIs versus other (non-ARB) comparators, 267 were studies of ARBs versus other (non-ACEI) comparators, and 194 were direct comparator studies of ACEIs versus ARBs.

Figure 1

Literature flow diagram

The remainder of this section describes results for the direct comparator studies. As stated above and described in Appendix B, we considered incorporating evidence from indirect studies for important outcomes that were under-reported in the direct comparator trials, but we were unable to identify a pool of comparable ACEI and ARB studies for this analysis.

At the full-text screening stage, 125 of the 194 direct comparator studies were excluded for the reasons summarized in Figure 1, leaving a total of 69 included articles. Appendix G provides a complete list of excluded head-to-head studies, with reasons for exclusion.

The 69 included direct comparator articles reported on 61 distinct studies. Forty-seven (47) of these were RCTs, one was a nonrandomized controlled trial, nine were retrospective cohort studies, two were prospective cohort studies, and one study each was a cross-sectional cohort and a case-control study. Table 3 describes the number of studies that evaluated various possible treatment comparisons.

Table 3

Number of included studies (number of publications) that evaluated various treatment comparisons

ACEIs | ARBs
ACEIs | “ARBs” | Candesartan cilexetil | Eprosartan | Irbesartan | Losartan | Olmesartan medoxomil | Telmisartan | Valsartan | Totals
“ACEIs” | 9 (11) | 1 (1) | 0 | 2 (2) | 2 (2) | 0 | 0 | 0 | 14 (16)
Benazepril | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Captopril | 0 | 0 | 0 | 0 | 2 (2) | 0 | 0 | 0 | 2 (2)
Enalapril | 0 | 4 (4) | 2 (6) | 4 (4) | 10 (12) | 0 | 3 (3) | 1 (1) | 24 (30)
Fosinopril | 0 | 0 | 0 | 2 (2) | 1 (1) | 0 | 0 | 0 | 3 (3)
Lisinopril | 0 | 4 (4) | 0 | 0 | 0 | 0 | 1 (1) | 3 (3) | 8 (8)
Moexipril | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Perindopril | 0 | 1 (1) | 0 | 0 | 1 (1) | 0 | 2 (2) | 0 | 4 (4)
Quinapril | 0 | 0 | 0 | 0 | 2 (2) | 0 | 0 | 0 | 2 (2)
Ramipril | 0 | 0 | 0 | 0 | 0 | 0 | 3 (3) | 0 | 3 (3)
Trandolapril | 0 | 0 | 0 | 0 | 1 (1) | 0 | 0 | 0 | 1 (1)
Totals: | 9 (11) | 10 (10) | 2 (6) | 8 (8) | 19 (21) | 0 | 9 (9) | 4 (4) | -

As Table 3 illustrates, enalapril was by far the most frequently studied ACEI (24 studies) and losartan the most frequently studied ARB (19 studies), followed by candesartan cilexetil (10 studies). The most commonly studied treatment comparison was enalapril versus losartan (10 studies), followed by the more generic “ACEIs” versus “ARBs” (9 studies). Other treatment comparisons were fairly sparsely represented.

In terms of quality, 39 studies were rated as fair, 17 as poor, and 5 as good. The distribution of studies by followup time is given in Table 4.

Table 4

Distribution of included studies by followup time

Treatment duration/followup time | Number of studies
12 weeks | 19
14–16 weeks/3–4 months | 8
24–26 weeks/6 months | 13
10–11 months | 2
48 weeks | 3
1 year | 7
15 months | 1
720 days | 1
3 years | 3
39 months | 1
4 years | 2
5 years | 1

There was no obvious correlation between study quality and length of followup. The five good-quality studies varied in length from 12 weeks (2 studies) to 16 weeks (1 study) to 1 year (2 studies).

## Key Question 1. For adult patients with essential hypertension, how do ACEIs and ARBs differ in blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes?

### Key Points

- There was no clear difference in the blood pressure lowering efficacy between ACEIs and ARBs.
- Few deaths or major cardiovascular events occurred in the identified studies comparing ACEIs to ARBs; this precluded any assessment of a differential effect of ACEIs and ARBs on these events.
- No significant difference was observed between ACEIs and ARBs in terms of their impact on quality of life.
- There was no statistically evident difference in rate of treatment success based on use of a single antihypertensive for ARBs compared to ACEIs.
- Available evidence suggests that ACEIs and ARBs have a similar lack of impact on lipid levels for individuals with essential hypertension.
- Available evidence suggests that ACEIs and ARBs have a similar lack of impact on glucose levels or HgbA1c for individuals with essential hypertension.
- Evidence does not demonstrate a difference between ACEIs and ARBs with regard to their effect on LV mass or function for individuals with essential hypertension.
- There are no consistently demonstrated differential effects related to renal function as measured by creatinine or GFR with use of ACEIs versus ARBs.
- There is a consistent finding of no differential effect related to reduction of urinary protein or albumin excretion among patients with essential hypertension with use of ACEIs versus ARBs.

### Effect on Blood Pressure

Fifty (50) studies described in 56 separate publications met our inclusion criteria and reported a blood pressure outcome. Of these, five (10 percent) were of good methodological quality,11–15 32 (64 percent; 37 papers) were of fair quality,16–52 and 13 (26 percent; 14 papers) were of poor quality.53–66 There was one nonrandomized controlled clinical trial,65 one retrospective cohort study,19 and one case-control study;63 the remaining 47 studies were RCTs. Sample sizes for individual studies ranged from 29 to 2416 patients, with a total of 16,597 patients (13,532 of whom received an ACEI or an ARB). Study durations ranged from 12 weeks to 5 years, with a median of 16.5 weeks.

The mean age of study participants ranged from 38 years to 73 years, with a median of 54.1 years. The proportion of female patients included ranged from 19 to 100 percent, with a median of 47 percent. Only 25 studies (50 percent; 30 papers) reported the racial demographics of the study participants.12–16,18,23–25,27–32,34,35,38,41,42,44–49,52,56,59,65 Of these 25 studies, only nine (36 percent; 13 papers) enrolled a minimum of 10 percent of ethnic minority participants.15,24,27–32,34,35,44,47,49 Seven of the included studies (14 percent; 11 papers) were conducted in part or entirely within the United States,15,24,27–32,34,35,49 with the remainder carried out in other countries. The funding source was reported in only 28 studies (56 percent; 33 papers),12–17,19,21–23,27–31,34,36–38,41,44,47–53,56,61–63,65 with the majority of these (23 studies) funded by the manufacturer of one of the study medications.

The mean systolic blood pressure (SBP) and diastolic blood pressure (DBP) at the beginning of each study ranged from 141 to 181 mm Hg and 84 to 119 mm Hg, respectively, with a mean starting blood pressure of 158.8/98.6 mm Hg. There was significant heterogeneity in the study protocols and data reporting. Fewer than half of the studies (22/50; 44 percent; 23 papers) did not allow additional hypertension medications during the study;11,18,22,24,25,33,34,36,38,40–43,45–48,50,51,56,59,65,66 18 studies (36 percent; 22 papers) allowed additional medications according to a specified protocol;12,14–17,20,23,27–32,35,37,39,44,49,54,60,63,64 five studies (10 percent; 6 papers) allowed additional medications at the discretion of the treating physician;13,19,21,52,61,62 and five studies (10 percent) did not report concomitant hypertension therapy.26,53,55,57,58 The reported blood pressure endpoints varied as well, with 13/50 studies (26 percent; 14 papers) reporting mean change in blood pressure and final posttreatment blood pressure;14,15,24,26,32,33,38,40,41,44–47,59 19 studies (39 percent; 20 papers) reporting only final posttreatment blood pressure;12,16–18,20,22,23,43,51,53–56,58,60–65 15 studies (30 percent; 19 papers) reporting only mean change in blood pressure in each study arm;11,13,19,21,25,27–31,34,35,39,42,48–50,52,66 and three studies (6 percent) not providing quantitative data for the blood pressure outcome or reporting only the proportion of patients achieving a target blood pressure.36,37,57

For the overall comparison of blood pressure lowering between ACEIs and ARBs, 37 studies reported no difference (74 percent; 42 papers),11–14,16–18,21–23,26–32,34–41,43,44,49,51–58,60–65 two studies favored ACEIs (4 percent; 3 papers),15,45,46 eight studies favored ARBs (16 percent),24,25,33,42,47,48,50,59 and three studies (6 percent) did not report the comparison between the two agents.19,20,66 We did not detect any specific ACEI or ARB that performed better or worse than other medications in its class.

Blood pressure outcomes were confounded by protocols calling for dose escalation or adding additional blood pressure lowering drugs; such protocols differed substantially between studies, making the blood pressure outcomes difficult to interpret. Overall, there was no clear difference in the blood pressure lowering efficacy between the two classes of agents, no matter what criteria were used for study inclusion. Because of the heterogeneity in study protocols, quantitative meta-analysis was not performed. However, despite some differences in methods for measuring successful control of blood pressure on a single agent, this outcome seemed to represent a reasonable comparison that was not confounded by substantial differences between studies. Therefore, quantitative meta-analysis was performed for this outcome.

Caveats and concerns include the fact that there was significant heterogeneity in the medication protocols and the use of concomitant hypertension therapy. Many of the studies reported limited data on patient characteristics, and black patients appeared to be significantly underrepresented overall. Very few of the studies were considered to be of good methodological quality. In addition, the majority of the studies reporting a funding source were sponsored by the manufacturer of the ARB.

### Effect on Mortality and Major Cardiovascular Events

The literature review identified 13 publications12–14,23,25,27–31,51,52,60 describing nine separate studies that reported patient mortality, MI, or clinical stroke as outcomes. All nine studies were RCTs. They included 3356 patients (3322 of whom received an ACEI or an ARB) and ranged in duration from 12 weeks to 5 years, and most reported blood pressure measurements as primary endpoints. The treatment comparisons studied were: candesartan versus enalapril, eprosartan versus enalapril, losartan versus enalapril, losartan versus fosinopril, telmisartan versus ramipril, telmisartan versus enalapril, and valsartan versus lisinopril.

In general the studies were of fair quality. Notably, the majority of studies in this review – including those reporting morality and major cardiovascular events – excluded patients with significant cardiovascular disease and often other comorbid conditions.

The included studies shed little light on the issue of relative rates of mortality, MI, or stroke with ACEIs versus ARBs. In nine studies involving 3356 patients, 16 patients died. The study by Barnett et al.52 provided the most and the longest-term data on cardiovascular events. This study evaluated telmisartan versus enalapril in 250 patients with type 2 diabetes and early nephropathy over a 5-year treatment period. In this higher risk population, cardiovascular events occurred at a similar rate in both treatment groups: there were six strokes in each group; nine nonfatal MIs in the telmisartan group and six in the enalapril group; and nine patients with heart failure in the telmisartan group and six in the enalapril group. This study also reported 12 deaths, six in the telmisartan group (three due to stroke, MI, and heart failure), and six in the enalapril group (two due to MI).

Among shorter-term trials, the study by Ruilope et al.,13 evaluating eprosartan versus enalapril over 12 weeks, reported one death in each group, a 95-year-old patient with cancer and an 80-year-old patient with heart failure. Shibaskaki et al.51 evaluated losartan versus enalapril versus amlodipine over 6 months and reported one death due to pulmonary hemorrhage, and one patient with MI; the treatment group to which the patient belonged was not specified for either event. The paper by Elliott et al.27 is the primary report of a trial of eprosartan versus enalapril over 26 weeks. A substudy from this trial published by Gavras et al.29 reported that one patient assigned to the eprosartan group had an anteroseptal MI and died. Finally, Williams et al.25 evaluated telmisartan versus ramipril over 14 weeks and reported that one patient in the ramipril group had a stroke. In none of these trials did investigators attribute any of the events observed directly to therapy.

Given the importance of this long-term outcome and the absence of significant data on major cardiovascular events, we turned to the indirect evidence (i.e., comparing an ACEI and an ARB to a common comparator, but not to each other.) However, this evidence was not deemed suitable for any indirect comparison (see Appendix B). In particular, a key risk factor for major events – namely, mean subject age – was widely discrepant in the small pool of potential indirect studies.

### Effect on Quality of Life

Four studies described in eight separate papers met our inclusion criteria and reported quality of life.27–31,39,43,50 All four were RCTs and were rated as fair in methodological quality. However, with regard to assessing quality of life, two of the four could be considered poor, as they did not present quantitative data.39,50

Sample sizes for the individual studies ranged from 42 to 528 patients, with a total of 1142 patients. Study durations ranged from 12 weeks to 3 years, with a mean of 55 weeks (median 26 weeks). Only one of the four studies reported the racial demographics of the study participants;27 in that study, 14 percent of participants were members of ethnic minorities. Studies utilized a variety of quality-of-life scales: two administered the Psychological General Well Being with its six subscales;27,50 two administered the Subjective Symptoms Assessment profile;27,43 one study employed the MacMaster Overall Treatment Evaluation Questionnaire;50 and one used the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36).39 Only two studies presented any quantitative data to support their conclusions of no difference in the impact of ACEIs or ARBs on quality of life.27,43

None of the studies found any difference between ACEIs and ARBs in their impact on the quality of life of study participants; indeed, no study demonstrated an impact on quality of life for subjects treated with ACEIs or ARBs.

### Effect on Rate of Use of a Single Antihypertensive Agent

We identified 22 studies that reported the outcome of successful monotherapy with an ACEI or ARB.13–21,23,28,32,33,35,37,39,49,54,60,63,64,67 The definition of “successful” monotherapy differed between studies and included SBP or DBP below a specified cutoff, or monotherapy defined by a lack of additional antihypertensive medication at the end of the study. Three of these studies were determined to be good quality, 15 were fair in quality, and four were poor. There were 19 RCTs, two retrospective cohorts, and one case-control study. Sample sizes ranged from 30 to 13,303 patients, with a total of 21,562 patients (12,010 of whom received an ACEI or ARB). Study durations ranged from 12 weeks to 3.3 years, with a median of 26 weeks. The rates of successful monotherapy ranged between 6 percent and 93.3 percent (median 61 percent). The average proportion for successful monotherapy across all studies was 55.9 percent for both ACEIs and ARBs.

We performed a meta-analysis of data from the 22 studies (Figure 2). Individual study estimates for the differences between ACEIs and ARBs in the proportion of patients achieving successful blood pressure control on a single agent showed no statistical heterogeneity (Q = 25.8; I2 = 18 percent; d.f. = 21; p = 0.22). A summary estimate of the difference in the proportion of patients with successful blood pressure control on a single agent was 1.3 percent (95 percent CI -1.0 to 3.5 percent; p = 0.26; random-effects model; results based on odds ratios and median incidence were similar). Because the definition of successful control of blood pressure with a single agent requires that a patient remain on the originally prescribed drug and receive no additional antihypertensive agent, “successful monotherapy” reflects both the efficacy of the medication and tolerability and adherence to the prescribed therapy. The trend favoring ARBs for this outcome appeared to be driven primarily by differences in tolerability and adherence, since the benefit of ARBs was heavily influenced by retrospective cohort studies, where medication discontinuation rates were higher in ACEI-treated patients, and by RCTs with very loosely defined protocols for medication titration and switching.

Figure 2

Successful monotherapy with ACEIs vs. ARBs

### Effect on Lipid Levels

Twelve studies described in 17 papers met our inclusion criteria and evaluated lipid changes. Eleven of the 12 studies were RCTs;11,12,17,18,23,26,27,40,45,60,64 one was an observational case-control study.63 The ACEI-versus-ARB treatment comparisons were unique in nine studies and similar (losartan versus enalapril) in three.23,45,63 Study periods ranged from 3 to 12 months, all of which were sufficiently long to detect measurable changes in the lipid profile.

Most of the 12 studies were fair in quality and none addressed the use of lipid-lowering agents during the study period. The two studies rated as good in quality11,12 were moderately sized (70 and 96), 1-year investigations of Europeans with diabetes; however, they differed in mean age, proportion of females, recruitment settings, and time of onset of diabetes.

The majority of the available head-to-head evidence suggests that ACEIs and ARBs have a similar lack of impact on lipid parameters. Six studies directly compared outcomes between ACEI and ARB groups.11,17,26,40,45,63 One study reported a decrease in LDL that was statistically greater in the ACEI group (perindopril -14 percent versus candesartan -4 percent),11 and one reported a statistically significant greater percentage of individuals with an increase in LDL in the enalapril group than in the candesartan group (19.3 percent versus 11.5 percent).17 Thus, for the two studies for which a difference was found, the difference was discrepant (i.e., an increase in LDL in one and a decline in LDL in the other). The remaining four studies that analyzed differences in outcomes between the two groups did not find a difference.

Nine studies found no change in total cholesterol (TC), low-density lipoprotein (LDL), high-density lipoprotein (HDL), or triglyceride (TG) levels during the study period. The remaining three studies detected a small but statistically significant change in TC (two studies23,60), LDL (one study11), and TG (one study60) (Table 5). The magnitude of these changes was equivalent for the compared medications except for one of the TC studies (ARB favored)60 and the LDL study (ACEI favored).11 Of these, only one was rated as good in quality.11

Table 5

Studies reporting significant changes in lipid profiles with ACEIs and/or ARBs

Study | N | Population | Quality | Comparators | ΔTC | ΔLDL | ΔHDL | ΔTG
Lacourciere et al.23 | 103 | - - Mean age 58; - - 96% white; - - Canada; - - Diabetes | Fair | Losartan vs. enalapril | −2.1% vs. +4.2%^*^ | NR | NR | NR
Derosa et al.11 | 96 | - - Mean age 54; - - 100% white; - - Europe; - - Diabetes | Good | Candesartan vs. perindopril | NR | −4% vs. −14%^*^ | +2% vs. −2% | +2% vs. −22%
Kavgaci et al.60 | 33 | - - Mean age 53; - - 100% white; - - Turkey; - - Diabetes | Poor | Losartan vs. fosinopril | +0.01% vs. −0.1%^*^ | NR | NR | −0.23%^*^ vs. −0.21%^*^

* Statistically significant change (baseline to followup)

Abbreviations: HDL = low-density lipoprotein; LDL = low-density lipoprotein; N = number of subjects; NR=not reported; TC = total cholesterol; TG = triglyceride

The study by Schram et al.,12 a broad-based community study comparing candesartan to lisinopril, found no change in lipid levels, while the study by Derosa et al.11 comparing candesartan to perindopril in newly diagnosed diabetics attending a university-based internal medicine outpatient clinic found an improvement in LDL (favoring perindopril, -14 percent versus −4 percent), but no change in other lipid parameters. The broader population of the first study makes it more generalizeable; however, it allowed the sequential addition of specified antihypertensives to achieve a goal blood pressure. This heterogeneity in medication use makes attributing the outcomes to any single agent difficult. Both studies are limited by a failure to include races other than Caucasians. There were two large studies, one of 407^45^ and one of 528 subjects.27 Both were rated as fair in quality and neither detected a change in lipid parameters.

### Effect on Markers of Carbohydrate Metabolism/Diabetes Control

Thirteen studies described in 18 papers met our inclusion criteria and measured glucose or HgbA1c. All but two63,65 were RCTs. Overall, only two studies were rated as good in quality;11,12 the remainder were rated as either fair (seven studies18,21,23,26,27,40,45) or poor (four studies60,63–65). The ACEI-versus-ARB comparisons tested were unique in seven studies; of the remaining six studies, enalapril and losartan were compared in four,23,45,63,65 and candesartan and lisinopril in two.12,21

It is relevant that none of the 13 studies measuring glucose or HgbA1c changes addressed hypoglycemic therapy during the study period, and only six were specifically performed in diabetic populations.11,12,21,23,40,60 Of the other seven studies, three permitted controlled diabetic patients but did not describe their proportion in the cohort;27,45,63 one permitted diabetic subjects, but they were in the minority (26 percent of subjects);18 and three specifically excluded individuals with diabetes.26,64,65

The majority of the available head-to-head evidence suggests that ACEIs and ARBs have a similar lack of impact on glucose levels or HgbA1c. Six studies directly compared outcomes between the ACEI and ARB groups.11,26,40,45,63,65 One study reported a small decrease in glucose that was statistically greater in the ACEI group (perindopril −15 ± 4 mg/dL, candesartan −8 ± 2 mg/dL),11 and one reported a significant increase in HgbA1c (+0.25 percent enalapril versus +0.6 percent losartan) but did not directly compare the two groups.23 Of these two studies only the former11 was rated as good in quality. The other five studies that analyzed differences in outcomes between the two groups did not find a difference. Eleven studies compared baseline to followup glucose levels or HgbA1c and found no change for either the ACEI or ARB groups.

### Effect on Measures of LV Mass or Function

Eight studies presented results on left ventricular (LV) mass or function assessed either by LV mass index (LVMI; 3 studies),43,63,65 LV ejection fraction (LVEF; 2 studies),53,58 or both (3 studies).37,51,56 Table 6 summarizes relevant characteristics of all eight studies. Half of these studies had fewer than 50 patients,43,51,53,65 while the other half had 100 or more patients.37,56,58,63 All but two studies63,65 were RCTs. Only two studies had relatively long-term followup ( 3 years);43,63 however, the majority of studies had between 6 and 12 months of followup,37,51,56,58,65 while one study had only 3 months of followup.53 Because duration of therapy may significantly impact the ability to observe changes in LV mass or LV function, negative results must be interpreted with caution in studies with short-term followup.

Table 6

Characteristics of studies reporting LV mass/function outcomes

Study | Agents studied | Population | Design and size^*^ | Duration | Quality | Outcome | Result
Cuspidi et al.37 | Candesartan vs. enalapril | LVH (29–32%) | RCT N = 196 (145) | 48 wk | Fair | LVMI & LVEF | ↓LVMI both, no difference between agents, no change in LVEF
Schieffer et al.53 | Irbesartan vs. enalapril | CAD (?%LVH) | RCT N = 60 (48) | 3 mo | Poor | LVEF | No difference No detailed data by treatment group
Avanza et al.65 | Losartan vs. enalapril | LVH (100%) | Non-rand controlled clinical trial N = 30 | 10 mo | Poor | LVMI | ↓LVMI both, no difference between agents, combo ACEI/ARB best
De Rosa et al.43 | Losartan vs. enalapril | LVH (44–53%) | RCT N = 50 (42) | 3 yr | Fair | LVMI | Non-statistical ↓LVMI both, no difference between agents
Shibasaki et al.51 | Losartan vs. enalapril | ESRD with LVH (100%) | RCT N = 20 | 6 mo | Fair | LVMI & LVEF | ↓LVMI both, ARB better than ACEI, no change in LVEF
Verdecchia et al.63 | Losartan vs. enalapril | LVH (23–24%) | Case-control N = 88 | 3.3 yr | Poor | LVMI | ↓LVMI both, no difference between agents
Rajzer et al.56 | Losartan vs. quinapril | HTN (?%LVH) | RCT N = 118 | 6 mo | Poor | LVMI & LVEF | No change in LVMI or LVEF in either group No detailed data by treatment group
Celik et al.58 | Telmisartan vs. ramipril | HTN (?%LVH) | RCT N = 100 | 6 mo | Poor | LVEF | No change in LVEF in either group

* Size of study includes total enrolled, with followup population (if different) in parentheses.

Abbreviations: CAD = coronary artery disease; ESRD = end-stage renal disease; HTN = hypertension; LVEF = left ventricular ejection fraction; LVH = left ventricular hypertrophy; LVMI = left ventricular mass index; mo = months; RCT = randomized controlled trial; wk = weeks; yr = years

Evidence provided by the eight studies identified did not demonstrate a difference between ACEIs and ARBs with regard to LV mass or function for individuals with essential hypertension. Six studies reported detailed data by treatment groups,37,43,51,58,63,65 while one reported summary data,56 and one described changes without presenting any data.53 In general, the quality ratings of these studies describing changes in LV mass or function was poor. None was rated as being a good-quality study, and the majority (n = 5) were assessed to be of poor quality.53,56,58,63,65 Various ARBs and ACEIs were studied, including five studies with losartan43,51,56,63,65 and six studies with enalapril.37,43,51,53,63,65 Among the six studies that presented detailed data on outcomes, three assessed LVMI,43,63,65 one assessed LVEF,58 and two assessed both LVMI and LVEF.37,51

The best and largest (n = 196) comparative study (an RCT) assessed LVMI and LVEF at baseline and after 48 weeks of followup.37 The authors reported similar decreases in mean LVMI in both groups in both intention-to-treat and per-protocol analyses (36.3 percent on candesartan with normalized LVMI versus 28.6 percent on enalapril). No significant changes were observed for LVEF. The trial with the longest followup (3 years; RCT) also reported similar reductions in mean LVMI in both groups; however, these changes did not reach statistical significance.43 Two non-randomized studies reported similar decreases in LVMI,63,65 with one65 demonstrating additional benefit in LVMI reduction with combination ACEI and ARB therapy. Only one study demonstrated a difference between groups for reduction in LVMI,51 with lower reduction among those treated with losartan versus enalapril (24.7 ± 3.2 percent versus 11.2 ± 4.1 percent; p = 0.026). However, definitive conclusions from this study are limited because it was conducted in patients with end-stage renal disease, included only 10 patients per treatment group, and had only moderate duration of followup (6 months). Finally, among the studies that reported results for LVEF, none demonstrated any differential effects between the ACEI and ARB groups.

Despite differences in sample size, study design, length of followup, study quality, therapeutic agents, and outcome measure, most of the studies demonstrated either similar improvements in LV mass or function between the ACEI and ARB groups37,51,63,65 or no change.43,56 Reductions in LVMI appear to have occurred particularly among patients with established LV hypertrophy.37,43,51,65 No changes in LVEF were observed in any of the studies. In sum, this body of poor- to fair-quality evidence does not demonstrate any differential effects in the ability of ACEIs and ARBs to improve or stabilize LVMI in patients with essential hypertension.

### Effect on Serum Creatinine/GFR and Proteinuria

Review of the literature on the relative effects of ACEIs and ARBs on changes in renal intermediate outcomes identified 20 studies described in 26 publications. One of these studies was conducted in patients with end-stage renal disease who had been on maintenance hemodialysis for at least 1 month.51 This study is not considered further here, as no changes would be expected in the outcome assessed (serum creatinine) in the population studied. Of the remaining 19 studies, nine assessed either serum creatinine or GFR;18,27,36,40,43,48,61,63,65 four assessed proteinuria;11,12,21,68 and six assessed both.17,23,45,52,55,60 Most studies included fewer than 100 patients; however, six had approximately 200 patients or more.21,27,36,45,48,52 All but three63,65,68 were RCTs. One study52 followed patients for 5 years, and approximately half of the studies had at least 1 year of followup; however, four studies followed patients for less than 4 months.36,40,45,61

The 15 studies that described changes in creatinine or GFR did not consistently demonstrate differential effects related to renal function with use of ACEIs versus ARBs. Nine of these studies reported detailed data by treatment groups,18,36,40,43,52,60,61,63,65 while two reported summary data,23,45 and four described the changes without presenting any quantitative data.17,27,48,55 Among the nine studies that reported data on renal function, none was rated as being a good-quality study; four were of poor quality;60,61,63,65 two were nonrandomized studies;63,65 and only two had more than 100 patients.36,52 All but two36,52 compared losartan with a specific ACEI; the ACEI most frequently studied was enalapril.43,52,61,63,65

The best comparative study assessed GFR by renal scintigraphy at baseline and after 3 years of followup.43 The authors reported increases in mean GFR in both groups, but there was no statistically significant difference between groups. One of the larger studies in this group (n = 190) reported a greater short-term increase (12-week study) in mean serum creatinine in the enalapril group (change 0.03 mg/dL [95 percent CI 0 to 0.06]) compared with the irbesartan group (change 0.01 mg/dL [95 percent CI −0.02 to 0.04]).36 Nonetheless, serum creatinine remained unchanged before and after treatment in the other studies that reported detailed data for this outcome (Figure 3).

Figure 3

Studies evaluating renal function for ACEIs vs. ARBs

Of two poor-quality studies that reported on changes in creatinine clearance, one reported no change.61 Although the other study reported significant and similar decreases in creatinine clearance in both groups,60 these changes did not correspond to the changes in serum creatinine reported, which calls into question the reliability of the data. Of the two studies that reported summary data, one found a nine percent mean decline in GFR assessed by radio-labeled excretion in each group (p < 0.001 at 52 weeks),23 while the other found no change in mean percent change in serum creatinine.45 Of the four studies that did not present data, two reported that there were no overall differences between groups;17,55 another that the degree and direction of insignificant change in renal function were comparable in both treatment groups;27 and the last described that 2 out of 192 patients treated with losartan developed an increase in serum creatinine during the 12-week study.48

The 10 studies that described changes in urine albumin or protein excretion consistently demonstrated no differential effects related to reduction of urinary protein or albumin excretion among patients with essential hypertension with use of ACEIs versus ARBs. Overall fair in quality, nine of 10 studies reported detailed data by treatment groups, while one reported summary data in graphical format.12 Among the nine studies that reported data, one was rated as being a good-quality study,11 three were of poor quality;55,60,68 one was a nonrandomized cohort study;68 and only three had more than 100 patients.21,45,52 Various ARBs were used, including one study with telmisartan,52 four studies with candesartan,11,17,21,68 three with losartan,23,45,60 and one with both candesartan and losartan.55 All studies assessed urinary albumin excretion except for one study that assessed urinary protein excretion.55 Studies also varied in length of followup, with only one long-term study (5 years);52 the remainder ranged from 12 weeks to 1 year. However, despite these differences in study quality, sample size, therapeutic agents, outcome measure and length of followup, all of the studies demonstrated declines in urinary protein/albumin excretion that were similar between the ACEI and ARB groups (demonstrated graphically for the four studies that could be included in the meta-analysis in Figure 4).

Figure 4

Studies evaluating urinary protein excretion for ACEIs vs. ARBs

The lack of an apparent differential impact of ACEIs versus ARBs on intermediate renal parameters must be considered in light of concerns about the available literature. Some concerns may reinforce the conclusion. For example, the study by Matsuda et al.55 provided sufficient data only on the subgroup of patients with moderate proteinuria and thus would likely favor ACEIs, yet there were no significant differential effects between the ACEI and ARB groups within the entire study sample after 48 weeks (p > 0.5). The five studies that reported data in a format that could not be included in the meta-analysis also failed to demonstrate a differential effect.21,23,45,52,60 On the other hand, because duration of therapy may significantly impact the ability to observe meaningful changes in renal function or proteinuria, negative results must be interpreted with caution in studies with short-term followup.

## Key Question 2. For adult patients with essential hypertension, how do ACEIs and ARBs differ in safety, adverse events, tolerability, persistence, and adherence?

### Key Points

- Cough was modestly more frequently observed as an adverse event in groups treated with ACEIs than in groups treated with ARBs.
- Withdrawals due to adverse events were modestly more frequent for groups receiving an ACEI rather than an ARB; this is consistent with differential rates of cough.
- No significant between-class differences were observed in the rates of any other commonly reported adverse events.
- Angioedema was reported only in patients treated with ACEIs; however, because angioedema was rarely explicitly reported in the included studies, it was not possible to estimate its frequency in this population.
- Adherence – in terms of pill counts in RCTs – is similarly high with both ACEIs and ARBs. However, persistence is generally lower with ACEIs, which appears to be explained largely by withdrawals due to cough (as above).

### Safety and Adverse Events

#### Rates of serious and overall adverse events

Seven studies met our inclusion criteria and reported overall rates of serious adverse events.14,17,24,25,36,39,48 One of these studies was rated as good in methodological quality, and the remaining six were fair. However, the nature of serious adverse event reporting was inconsistent, and rates of serious adverse events were low (on the order of 0 to 6 percent, depending on definition); thus, data on these events were not deemed useful for assessing a differential effect of ACEIs versus ARBs.

A potentially salient and serious adverse event, angioedema, was reported in only 3 of the 61 included studies (Table 7).32,39,41 All of the reported cases occurred in patients treated with an ACEI. We did not pool these studies for two reasons. First, if we restricted pooling to the 3 studies, this did not meet our criterion for the minimal number of studies in a pool (n = 4). Second, if we included all 61 studies, it was not clearly valid to infer that there were no events simply because the study did not report explicitly that an episode of angioedema did not occur. Thus we are unable to estimate the frequency of angioedema in this population.

Table 7

Studies reporting angioedema

Study | Study design (blinding) | Interventions (numbers of patients) | Duration | Quality | Results
Karlberg et al.39 | RCT (double-blinded) | Telmisartan (n = 139) Enalapril (n = 139) | 26 weeks | Fair | No cases of angioedema with telmisartan 1 case (“severe disabling Quincke’s angioneurotic edema”) with enalapril
McInnes et al.41 | RCT (double-blinded) | Candesartan (n = 237) Lisinopril (n = 116) | 26 weeks | Fair | No cases of angioedema with candesartan 2 cases with lisinopril
Neutel et al.32 | RCT (double-blinded) | Telmisartan (n = 385) Lisinopril (n = 193) | 48 weeks | Fair | No cases of angioedema with telmisartan 2 cases with lisinopril

Of the 29 studies that met inclusion criteria and reported overall adverse event rates,11,13–15,17,24,25,27,32–39,41,42,45,47–50,52,54,57,59,61,66 most were assessed as being fair (20 studies) or poor (five studies) in quality, and there was significant variation in the manner in which adverse events were reported. Depending on the definition used, adverse event rates ranged from 0 to 100 percent (median 32 percent) for ACEIs, and 0 to 96 percent (median 28 percent) for ARBs. Thus, data on overall rates of adverse events were not considered further.

#### Specific adverse events

Thirty studies reported rates of one or more specific adverse events,11,13–15,23–25,27,32–39,41–45,47–50,57,59,68–70 including cough (29 studies), headache (21 studies), dizziness (18 studies), fatigue (10 studies), upper respiratory infection (6 studies), and nausea (6 studies). Viral infection, ankle edema, and back pain were reported as adverse events by three studies each. Palpitations, myalgia, diarrhea, malaise, and hypotension were reported by two studies each. Accident/injury, pharyngitis, rhinitis, dyspnea, abdominal pain, abnormal taste, urinary tract infection, constipation, dry mouth, feeling sick, pyrosis, insomnia, fever, asthenia, impotence, dyspepsia, musculoskeletal pain, flatulence, epigastric discomfort, increased sweating, erythematous rash, rhinitis, sinusitis, vertigo, flushing, cold hands/feet, adverse events related to the nervous system, adverse events related to the cardiovascular system, and adverse events related to the gastrointestinal system were reported as a specific adverse events by one study each.

Given the large number of commonly reported specific adverse events, we focused on three specific events with the largest difference in absolute rates across studies: dizziness, headache, and cough. Rates of dizziness in studies reporting this event (n = 18) ranged from 1 to 20 percent in ARB-treated groups (mean 6 percent, median 4 percent) and from 0 to 18 percent in ACEI-treated groups (mean 7 percent, median 5 percent). For headache (n = 21 studies), rates ranged from 1 to 22 percent in ARB-treated groups (mean 8 percent, median 7 percent) and from 0 to 34 percent in ACEI-treated groups (mean 10 percent, median 7 percent). Our analysis of these figures showed no significant differences between ACEIs and ARBs (risk difference for dizziness 0.1 percent in favor of ACEIs, p = 0.805, fixed-effect model; risk difference for headache 0.7 percent in favor of ARBs, p = 0.069, fixed-effect model). These results suggest that there is no differential impact of ACEIs and ARBs with regard to dizziness or headache.

The one adverse event for which significant differential effects were apparent is cough. Twenty-nine studies compared cough in subjects treated with ACEIs and ARBs. In terms of quality, four were rated as good, 20 as fair, and five as poor. Of the 29 studies, 26 were RCTs, two were prospective cohort studies, and one was a cross-sectional cohort study. Sample sizes for the studies ranged from 49 to 51,410 patients, with a total of 61,978 patients. Study durations ranged from 12 weeks to 3 years, with a median of 16 weeks. The mean patient age of study participants was 57 years (standard deviation [SD] 6.25). The proportion of female patients included ranged from 19 to 100 percent. Eighteen studies (62 percent) reported the racial demographics of the study participants. Of these 18 studies, eight (44 percent) enrolled a minimum of 10 percent of ethnic minority participants.

Rates of cough in these studies ranged from 0 to 13 percent for ARB-treated groups (mean 3 percent, median 1 percent) and from 0 to 23 percent in ACEI-treated groups (mean 10 percent, median 9 percent). All 29 studies demonstrated higher rates of cough in ACEI-treated participants. For the meta-analysis of studies reporting cough as an adverse event, we included all studies that reported on cough rates (Figure 5). The Q test and the I2 between studies demonstrated significant heterogeneity among the studies (Q = 57.5; I2 = 51.3 percent). Performing a meta-analysis using a random-effects model leads to an estimated odds ratio (Peto) of 0.32 in favor of ARBs (95 percent CI 0.29 to 0.36; p = 0.000). Notably, the observed rates of cough appear much higher in RCTs than cohort studies; this is due to the higher detection when the patient is queried systematically for this symptom. Thus, based on the overall odds ratio of 0.32, when we use the rate of cough with ACEIs equal to the RCTs (9.9 percent) the absolute rate difference is estimated to be 6.7 percent (NNT = 15); however, when we use the rate of cough with ACEIs equal to the cohort studies (1.7 percent) the absolute rate difference is estimated to be 1.1 percent (NNT = 87). The latter estimate is likely to be more clinically relevant.

Figure 5

Studies reporting on cough with ACEIs vs. ARBs

#### Withdrawals due to adverse events

Twenty-four (24) studies met our inclusion criteria and reported withdrawals due to adverse events.12,14,21,23,27,32,34–39,41–45,47,48,52,57,61,63,65 Of these, two (eight percent) were of good methodological quality, 18 (75 percent) were fair in quality, and four (17 percent) were poor. Twenty-two studies were RCTs, one was a nonrandomized controlled clinical trial, and one was a case-control study. Sample sizes for the individual studies ranged from 46 to 1213 patients, with a total of 7664 patients. Study durations ranged from 12 weeks to 5 years, with a mean of 49 weeks (median 25 weeks). The mean age of study participants was 55 years (SD 5). The proportion of female patients included ranged from 19 to 59 percent, with a mean of 46 percent. Fifteen studies (63 percent) reported the racial demographics of the study participants. Six of these (25 percent of the 24 total studies) enrolled a minimum of 10 percent of ethnic minority participants, while five enrolled only white patients.

Rates of withdrawals due to adverse events ranged from 1 to 41 percent, with a mean of 10 percent (median 3 percent) for patients on ARBs, and a mean of 19 percent for patients on ACEIs (median 8 percent). Trials almost uniformly favored ARBs (i.e., there were more withdrawals in ACEI-treated groups). However, there was significant variation in the study protocols and data reporting.

We conducted a meta-analysis of all 24 studies that reported withdrawals due to adverse events (Figure 6). Sixteen studies demonstrated higher rates in ACEI-treated participants; three studies demonstrated higher rates in ARB-treated participants; and five showed no difference in withdrawal rates. For the pooled odds ratio, the Q test and the I2 between studies demonstrated modest heterogeneity between studies (Q = 36.0; I2 = 36.2 percent). The meta-analysis revealed that the odds ratio (Peto) for withdrawal rate favored ARBs (0.51; 95 percent CI 0.38 to 0.70; random-effects model). For the median withdrawal rate (8 percent for ACEIs) the absolute difference in withdrawal rate is estimated to be 3.7 percent (NNT = 27).

Figure 6

Studies reporting withdrawals due to adverse events for ACEIs vs. ARBs

Caveats and concerns in relation to these data include the fact that only one study was considered to be of good methodological quality. Also, there was significant heterogeneity in the reporting of withdrawal data. Many studies reported limited data on withdrawal rates. Moreover, only one trial analyzed data to assess variation in withdrawal rates by specific demographic subgroups.70

### Adherence and Persistence

Nineteen papers describing 17 distinct studies reported at least some quantitative information on persistence or adherence.16,17,19,25,38,41,42,50,57,67,71–79 Studies of adherence consisted of RCTs that assessed reported pill counts or subject dropout. Since subject dropout did not uniformly reflect adherence with medication (as opposed to adherence with the study protocol, for example), we focused on the seven studies that measured pill counts. Studies of persistence – whether patients remain on the initial ACEI or ARB – included two RCTs as well as nine longitudinal cohorts in which patients were followed in a real-world setting. While adherence and persistence were lower in cohort studies than in the randomized trials, the general conclusions from the two groups of studies were similar.

With the possible exception of the study by Koylan et al.,57 adherence with ACEIs and ARBs was similar (Table 8). Moreover, adherence was high, above 97 percent in five of the seven studies assessed. All of the studies appeared to define adherence as the percentage of patients taking approximately 100 percent of the prescribed pills, although not every article was precise in reporting how this figure was derived. The absolute magnitude of adherence depended on the width of the acceptable range (e.g., McInnes et al.41 used a narrow range of 90 to 110 percent of prescribed pills, so might be expected to report lower adherence than Malmqvist et al.,50 which considered a wider range of 75 to 125 percent of prescribed pills to be acceptable). Also, randomized trials, which engender such biases as motivated volunteers and a Hawthorne effect, will tend to overestimate adherence in comparison with usual practice. Nevertheless, the overall conclusion that adherence was good and similar between ACEIs and ARBs seems well supported.

Table 8

Studies of adherence with ACEIs and ARBs

Study | Adherence with ACEIs | Adherence with ARBs | Definition of adherence
Amerena et al.42 | 99% | 99% | Pill counts at 6 weeks
| 98% | 98% | Pill counts at 12 weeks
Coca et al.38 | 98.4% | 98.3% | Taking 80–110% of pills
Koylan et al.57 | ~ 94% | ~ 96% | Taking pills daily at 1 month visit
Koylan et al.57 | ~ 86% | ~ 96% | Taking pills daily at 3 month visit
Koylan et al.57 | ~ 87% | ~ 96% | Taking pills daily at 6 month visit
Malmqvist et al.50 | > 98% | > 98% | Taking 75–125% of pills at 6 weeks
Malmqvist et al.50 | > 98% | > 98% | Taking 75–125% of pills at 12 weeks
McInnes et al.41 | 90% | 90% | Taking 90–110% of pills
Rosei et al.17 | 98.2% | 97.8% | Not specifically defined
Williams et al.25 | > 98.8% | > 98.8% | Taking 80–120% of pills

Regarding persistence, the majority of evidence came from nonexperimental studies, which are subject to a variety of caveats, described below. These caveats notwithstanding, the results were quite consistent in that persistence with ARBs was modestly better than persistence with ACEIs (Table 9). Noting both the consistency of this finding across studies and the rather modest degree of differences in persistence, the conclusion that ARBs exhibit somewhat better persistence than ACEIs can be drawn with a moderate degree of confidence.

Table 9

Studies of persistence with ACEIs and ARBs

Study | Duration | ACEIs | | | ARBs
Study | Duration | Continued | Switched | Discontinued | Continued | Switched | Discontinued
Randomized trials
Saito et al.16 | 6 mo | 71% | 28% | 2% | 89% | 9% | 2%
Koylan et al.57 | 6 mo | ~ 82% | - | - | ~ 89% | - | -
Longitudinal cohort studies
Hasford et al.19 | 1 yr | 42% | - | - | 44.7 to 60.8% | - | -
Mazzaglia et al.67 | 1 yr | ~ 50% | ~ 8% | ~ 42% | ~ 50% | ~ 10% | ~ 40%
Bloom et al.71/Conlin et al.73 | 1 yr | 58% | 9% | 33% | 64% | 7% | 29%
Bloom et al.71/Conlin et al.73 | 4 yr | 46.5% | 18.9% | 34.6% | 50.8% | 16.5% | 32.7%
Erkens et al.76 | 1 yr | 59.7% | - | - | 62.0% | - | -
Marentette et al.77 | 1 yr | - | - | ~ 35% | - | - | ~ 15%
Bourgault et al.72 | 1 yr | - | - | 41% | - | - | 34%
Bourgault et al.72 | 2 yr | - | - | 53% | - | - | 44%
Bourgault et al.72 | 3 yr | - | - | 60% | - | - | 47%
Burke et al.79 | 1 yr | - | - | 37.8% | - | - | 29.4%
Burke et al.79 | 2 yr | - | - | 48.0% | - | - | 41.3%
Burke et al.79 | 3 yr | - | - | 54.8% | - | - | 50.3%
Burke et al.79 | 4 yr | - | - | 60.4% | - | - | 57.8%
Wogen et al.78 | 1 yr | 50% | - | - | 63% | - | -
Degli Esposti et al.74,75 | 1 yr | 30.7% | 9.4% | 59.9% | 33.4% | 24.6% | 42.0%

The results of the longitudinal studies should be considered in light of several caveats. The longitudinal cohort studies typically use administrative databases and, even though investigators control for differing patient characteristics as much as possible, this design cannot assure that patients receiving different medications are similar, even after statistical adjustment. Consequently, the consistency of results across multiple studies is crucial. Results of multi-predictor analyses, when present, yielded substantially similar conclusions to the simple comparison of unadjusted persistence provided above; accordingly, we focus on the unadjusted results.

The ideal outcome would disaggregate patients into four mutually exclusive and exhaustive categories: (1) continued initial medication without change; (2) continued initial medication but added another medication from a different class; (3) changed to another medication from a different class; and (4) discontinued medication entirely. Almost all of the reports aggregated the first two categories, which we have combined throughout. Within each category, definitions are not entirely consistent, but are close enough for purposes of comparison.

As a final caveat, several of the longitudinal cohort studies (e.g., Marentette et al.,77 Bourgault et al.,72 Burke et al.,79 Wogen et al.,78 and Degli Esposti et al.74,75) corresponded in time to the introduction of ARBs, and thus have relatively small sample sizes for this class of medication. Accordingly, for these studies persistence is estimated with less precision than might be desired.

## Key Question 3. Are there subgroups of patients based on demographic characteristics (age, racial and ethnic groups, sex), use of other medications concurrently, or comorbidities for which ACEIs or ARBs are more effective, associated with fewer adverse events, or better tolerated?

### Key Points

- Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACEIs and ARBs for any particular patient subgroup.

### Blood Pressure

We did not identify any subgroup of patients in which one ACEI or ARB was clearly superior. Two of 50 studies reporting blood pressure outcomes included only women,26,50 and two additional studies reported results for a female subgroup.39,47 Three of these four found no significant difference in blood pressure effects between the ACEI and the ARB treatment arms; however, the largest of these studies reported superior blood pressure lowering in the ARB arm compared to the ACEI (n = 286, mean between group difference 5.5/2.2 mm Hg; p ≤ 0.01).50 There were three studies conducted exclusively in elderly patients (age ≥ 65), and three additional studies that reported separate results for this age group.13,28,33,35,39,47 Four of these studies showed no difference between ACEI and ARB treatment in elderly patients,13,28,39,47 and two studies reported better blood pressure lowering in the ARB arm.33,35 Eight studies were conducted only in diabetic patients with hypertension, none of which showed a difference between the two classes of medication.11,12,17,21,23,40,52,60 In four studies, blood pressure was reported as an outcome in a subgroup of black patients.15,30,35,44 Three of these studies found no difference in the efficacy of ACEIs versus ARBs in black patients, while one reported significantly better DBP lowering in ARB-treated patients compared to ACEI-treated patients.35

### Mortality and Major Cardiovascular Events

Because of scant data on mortality, MI, and stroke, it was not possible to assess whether ACEIs and ARBs have any differential effect on event rates in any subgroups of patients based on demographic characteristics, use of other medications concurrently, or comorbidities.

### Quality of Life

None of the included trials reported any differential impact of ACEIs versus ARBs on quality-of-life measures by clinically relevant subgroup.

### Safety and Adverse Events

In general, there is no evidence supporting differential rates of adverse events for ACEIs versus ARBs with regard to any specific subgroup. However, one study included only women in the study population.50 The overall rates of cough reported by the study were similar to those reported by other studies that included men and women. One study reported results for a female subgroup.70 The proportion of women in the latter study was 55.7 percent, and rates of cough in this study were higher for women treated with ACEIs (statistically significant for two of the three ACEIs studied in the trial) than they were for women treated with ARBs.

### Adherence and Persistence

There is not sufficient evidence that particular patient subgroups are more or less likely to be persistent in taking an ACEI versus an ARB. However, some observations emerge regarding persistence with either agent (Table 10). The most consistent result is that persistence increased with age: patients in the 65-to-84-year-old age range tended to exhibit the highest persistence of all. The contribution of sex was inconsistent. There is some evidence that a history of cardiovascular disease is associated with greater persistence, a possible explanation being that such a history could make hypertension management more salient to the patient.

Table 10

Predictors of persistence with ACEIs and ARBs

Study | Predictors of persistence
Mazzaglia et al.67 | Increasing age, family history of cardiovascular diseases and diabetes, no severe hypertension, low chronic disease score
Bloom et al.71 (1yr)/Conlin et al.73 (4 yr) | 1 yr: Increasing age, < 1 dose per day, male sex 4 yr: Increasing age, female sex
Erkens et al.76 | Increasing age, male sex, antidiabetic drugs, lipid lowering drugs, previous cardiovascular hospitalizations
Marentette et al.77 | Increasing age, female sex
Degli Esposti et al.74 (1 yr)/Degli Esposti et al.75 (3 yr) | 1 yr: Increasing age, medications for heart disease or diabetes, previous cardiovascular hospitalizations, ≥ 2 comorbidities 3 yr: Increasing age, male sex, younger general practitioner, male sex of general practitioner

### Lipids

Several potentially relevant subgroups were identified, but none had a clear difference in outcomes for lipid parameters. Six studies evaluated patients with diabetes.11,12,21,23,40,60 These included three that found small changes in various lipid parameters,11,23,60 but the other three found none.12,21,40 Other populations studied – including postmenopausal women,26 Asians,18 and Turks60 – did not have detectable changes in the lipid profile.

### Diabetes Markers

In the six studies requiring diabetes as an inclusion criteria, four found no difference in individuals receiving ACEIs or ARBs in glucose or HgbA1c levels;12,21,40,60 one found no change in glucose but a small statistically significant increase in HgbA1c for the ARB (+0.25 percent enalapril, +0.6 percent losartan; data not reported for between-group comparisons);23 and one found no change in HgbA1c but a decline in glucose levels for both which was statistically greater for the ACEI (perindopril −15 ± 4 mg/dL, candesartan −8 ± 2 mg/dL).11 Thus, for the two studies for which a difference was found, the difference was discrepant (i.e., an increase in HgbA1c in one and a decline in glucose in the other), and only one directly analyzed differences between the two groups.

In addition to studies of individuals with diabetes, measures of glucose or HgbA1c were performed for several other subgroups including Asians,18 Turks,60 Brazilians,65 and postmenopausal women.26 None of these studies identified a difference in the impact of ACEIs and ARBs with regard to glucose or HgbA1c.

### LV Mass/Function

Although five of the eight studies that presented results on LV mass or function demonstrated some decreases in LVMI, the sum of the evidence does not demonstrate a difference between ACEIs and ARBs with regard to their effect on LV mass or function for individuals with essential hypertension. No subgroup analyses were performed in the included studies to help identify subgroups of patients who were more likely to have improvements in LV mass or function in any of the studies.

### GFR/Proteinuria

There are no consistently demonstrated differential effects with use of either ACEIs or ARBs related to either renal function (as measured by creatinine or GFR) or reduction of urinary protein or albumin excretion. As a result, we were not able to identify subgroups of patients for whom either ACEIs or ARBs are more effective in preserving renal function or decreasing urinary protein or albumin excretion, or are better tolerated without causing sustained elevations in serum creatinine.