# Methods

## Topic Development

The topic for this report was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) for the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program drafted the initial key questions and, after approval from AHRQ, posted them to a public Web site. The public was invited to comment on these questions. After reviewing the public commentary, the SRC drafted final key questions and submitted them to AHRQ for approval.

## Search Strategy

We conducted a comprehensive search of the scientific literature to identify systematic reviews, randomized controlled trials, and nonrandomized comparative studies relevant to the key questions. Searches of electronic databases used the National Library of Medicine’s Medical Subject Headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. Searches included terms for drug interventions, hypertension, and study design, and were limited to studies published in English after 1988. The texts of the major search strategies are given in Appendix A. We also reviewed selected materials received from the SRC, the reference lists of relevant review articles, and citations identified by peer and public reviewers of the draft report. We did not undertake a systematic search for unpublished data.

To identify literature describing direct comparisons of ACEIs versus ARBs we searched:

- MEDLINE^®^ (1966 to May Week 3 2006).
- The Cochrane Central Register of Controlled Trials.
- A register of systematic reviews underway in the Cochrane Hypertension Review Group.
- Scientific information packets submitted through the SRC by AstraZeneca, Bristol-Myers Squibb, Kos, and Merck.

We conducted additional searches in MEDLINE^®^ for studies of ARBs versus other (non-ACEI) comparators and ACEIs versus other (non-ARB) comparators for potential use in the event that evidence from direct head-to-head trials proved to be insufficient for some or all of the outcomes of interest in this review. The search strategies used to identify this potentially relevant indirect comparator literature are included in Appendix A. The process used to screen this literature and evaluate its relevance is described in Appendix B.

Our searches identified a total of 1,185 citations. We imported all citations into an electronic database (ProCite^®^ 4).

## Study Selection

We developed criteria for inclusion and exclusion based on the patient populations, interventions, and outcome measures specified in the key questions. The abstract screening criteria we used (Appendix C) were designed to identify potentially relevant indirect comparator studies (ACEI versus non-ARB or placebo and ARB versus non-ACEI or placebo), as well as direct head-to-head comparator studies. We retrieved the full text of all potentially relevant abstracts for further review. In the case of direct comparator studies, we applied a second, more stringent set of criteria for inclusion and exclusion (Appendix C). Full-text screening of the indirect comparative literature proceeded along a separate track, which is described in Appendix B.

The remainder of this section describes in greater detail the criteria we used to screen the direct comparator literature.

### Population and Condition of Interest

As specified in the key questions, this review focused on adult patients (age 18 years or older) with essential hypertension, as defined by study authors. We included studies with patients of mixed ages and mixed diagnoses only if results were reported separately for the relevant subgroups.

### Interventions and Comparators of Interest

We included the ACEIs and ARBs listed in Table 1. In addition to straightforward comparisons of a single ACEI versus a single ARB, we also included “grouped” comparisons (e.g., a specific ARB versus “ACEIs” or unspecified “ARBs” versus unspecified “ACEIs”) and comparisons of an ACEI + drug X versus an ARB + drug X (e.g., losartan + hydrochlorothiazide [HCTZ] versus enalapril + HCTZ). We excluded comparisons of an ACEI + drug X versus an ARB + drug Y (e.g., enalapril + manidipine vs. irbesartan + HCTZ).

Table 1

Characteristics and labeled indications of ACEIs and ARBs evaluated in this report

Drug (trade name) | Half-life and other relevant pharmacokinetic features | Labeled indications | Dosing for treatment of hypertension | Dose adjustments for special populations
ACEIs
Benazepril (Lotensin^®^) | - - After oral administration, peak plasma concentrations reached within 0.5–1 hr.; - - Effective half-life in adults following multiple dosing 10–12 hr.; - - Cleared predominantly by renal excretion in subjects with normal renal function. | Treatment of hypertension. May be used alone or in combination with thiazide diuretics. | Initial dose for adults not receiving a diuretic is 10 mg once daily. Usual maintenance range is 20–40 mg per day in a single or two equal doses. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - In patients with renal insufficiency (creatinine clearance ≤ 30 mL/min/1.73 m2) peak levels and initial half-life increase, time to steady state may be delayed.; Recommended initial dose in such patients is 5 mg once daily. Dosage may be titrated upward until BP is controlled or to a maximum total daily dose of 40 mg.
Captopril (Capoten^®^) | - - After oral administration, peak plasma concentrations reached in 1 hr. Presence of food reduces absorption by 30–40%.; - - In adults, effective half-life < 3 hr (accurate determination of half-life not possible).; - - In a 24-hr period, 95% of observed dose eliminated in the urine.; - - Reduction of BP maximum at 60–90 minutes after oral administration, duration of effect dose-related.; - - Reduction in BP may be progressive. | 1. Treatment of hypertension.; 2. Treatment of congestive heart failure.; 3. To improve survival following MI in clinically stable patients. | Should be taken 1 hr before meals, dosage must be individualized. Initial dose is 25 mg twice per day or three times per day. Dosage may be increased to 50 mg twice per day or three times per day. Usual dose range is 25–150 mg twice per day or three times per day. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Patients with renal impairment: initial daily dose should be reduced, smaller increments should be utilized for titration, and minimal effective dose should be calculated.
Enalapril (Vasotec^®^) | - - After oral administration, peak serum concentrations occur within 1 hr.; - - Primarily renal, 94% of dose is recovered in the urine and feces.; - - Effective half-life following multiple doses is 11 hr.; - - With GFR ≤ 30 mL/min, time to peak concentration and steady state delayed. | Treatment of hypertension. | 10–40 mg per day in a single or two divided doses. Daily dose should not exceed 50 mg. Dosage reduction and/or discontinuation may be required for some patients who develop increases in blood urea and serum creatinine. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus. Enalapril has been detected in human breast milk.; - - Dose selection for elderly patients should be cautious, usually starting at the low end of the dosing range.
Fosinopril (Monopril^®^) | - - After oral administration, peak concentrations achieved in 3 hr.; - - Terminal elimination half-life is 12 hr.; - - Cleared predominantly by renal excretion in subjects with normal renal function. | 1. Treatment of hypertension. May be used alone or with thiazide diuretics.; 2. For heart failure as adjunctive therapy when added to conventional therapy, including diuretics with or without digitalis. | Initial dosage is 10 mg once daily, both as monotherapy and when the drug is added to a diuretic. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - In children, doses between 0.1 and 0.6 mg/kg. For children weighing more then 50 kg, dosage is 5–10 mg once daily.; - - For heart failure patients, an initial dose of 5 mg can be increased over a several-week period but not exceeding 40 mg once daily.
Lisinopril (Prinivil^®^; Zestril^®^) | - - Reaches peak serum concentrations within 7 hr.; - - On multiple doses, effective half-life accumulation is 12 hr.; - - Excreted primarily through the kidneys. | 1. Treatment of hypertension.; 2. As adjunctive therapy in the management of heart failure not responding to diuretics and digitalis.; 3. Acute MI – for the treatment of hemodynamically stable patients, to improve survival. | Initial dose is 10 mg once daily, usual dose range 20–40 mg daily in a single dose. Patients on a diuretic dosage should be adjusted according to BP response, and the diuretic should ideally be discontinued. For patients with creatinine clearance ≤ 10 mL/min, recommended initial dose is 2.5 mg, can be titrated upward up to a maximum of 40 mg daily. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Dose selection for elderly patients should start at the low end of dosing range.
Moexipril (Univasc^®^) | - - Bioavailability of oral drug is 13% compared to IV; markedly affected by food.; - - After oral administration, 7% appears in urine (vs. 40% of IV dose), 52% in feces (vs. 20% of IV dose). | Treatment of hypertension. | Initial dose in patients not receiving diuretics is 7.5 mg 1 hr prior to meals, once daily. Recommended dose range is 7.5–30 mg daily in one or two divided doses. Diuretic therapy should ideally be discontinued or an initial dose of 3.75 mg should be used with medical supervision. For patients with creatinine clearance ≤ 40 mL/min/1.73 m2, the recommended initial dose is 3.75 mg once daily, can be titrated to a maximum daily dose of 15 mg. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Dosage should be adjusted for populations with decreased renal function, mild to moderate cirrhosis and in elderly patients.
Perindopril (Aceon^®^) | - - After oral administration, peak plasma concentrations occur at approximately 1 hr.; - - Mean half-life 0.8–1.0 hr.; - - Clearance almost exclusively renal. | 1. Treatment of hypertension. May be used alone or in combination with thiazide diuretics.; 2. Stable coronary artery disease: to reduce risk of cardiovascular mortality or nonfatal MI. | Initial dose is 4 mg once daily. May be titrated upward until BP is controlled to a maximum of 16 mg per day. Usual dose range is 4–8 mg as single daily dose. May be given in two divided doses. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Dose selection for elderly patients should start at the low end of dosing range.; - - Patients with renal impairment: initial daily dose should be reduced.
Quinapril (Accupril^®^) | - - After oral administration, peak plasma concentrations reached within 1 hr.; - - After multiple oral dosing, effective half-life within 2 hr.; - - Cleared predominantly by renal excretion in subjects with normal renal function. | 1. Treatment of hypertension. May be used alone or with thiazide diuretics.; 2. Management of heart failure as adjunctive therapy when added to conventional therapy, including diuretics and/or digitalis. | Initial dosage for patients not on diuretics is 10–20 mg once daily. Dosage adjusted according to BP measured at peak and trough. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Patients with renal impairment and heart failure: initial daily dose should be reduced.; - - Recommended dosage for elderly patients is 10 mg once daily followed by titration to the optimal response.
Ramipril (Altace^®^) | - - After oral administration, peak plasma concentrations reached within 1 hr.; - - Cleared predominantly by renal excretion in subjects with normal renal function. | 1. Treatment of hypertension. May be used alone or in combination with thiazide diuretics.; 2. Reduction in risk of MI, stroke, and death from cardiovascular causes for patients 55 years or older at high cardiovascular risk. | Initial dose for patients not receiving a diuretic is 2.5 mg once daily. Dosage adjustment according to BP response. Usual maintenance dosage is 2.5–20 mg once daily in a single dose or divided equally into 2 doses. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Patients with renal impairment: initial daily dose should be reduced, smaller increments should be utilized for titration and minimal effective dose should be calculated.
Trandolapril (Mavik^®^) | - - After oral administration under fasting conditions, peak concentrations occur within 1 hr.; - - Effective half-life approximately 6 hr.; - - Cleared predominantly by renal excretion in subjects with normal renal function. | 1. Treatment of hypertension. May be used alone or with other antihypertensive medication.; 2. Heart failure post-MI or LV dysfunction post-MI. Used to decrease risk of death and heart failure-related hospitalization. | Initial dosage in patients not receiving a diuretic is 1 mg once daily in patients who are not black and 2 mg in black patients. Dosage adjusted according to BP. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Patients with renal impairment: initial daily dose should be reduced, smaller increments should be utilized for titration and minimal effective dose should be calculated.
ARBs
Candesartan cilexetil (Atacand^®^) | After oral administration, peak serum concentrations reached after 3–4 hr.; - - Elimination of half-life occurs within 9 hr.; - - Excreted in urine and feces. | 1. Treatment of hypertension. May be used alone or in combination with other antihypertensive agents.; 2. Heart failure: used in patients with LV systolic dysfunction to reduce risk of death and heart failure. | Initial dose is 16 mg once daily. Can be given once or twice daily with doses ranging from 8–32 mg. Effect is usually present within 2 weeks, and maximal BP reduction occurs within 4–6 weeks. | - - When used in pregnancy during the second and third trimesters, ACEIs can cause injury and even death to the developing fetus.; - - Lower dose for patients with moderate hepatic impairment or depletion of intravascular volume.
Eprosartan (Teveten^®^) | - - After oral administration, plasma concentrations peak around 1–2 hr in the fasted state.; - - Mean terminal elimination half-life following multiple doses of 600 mg was 20 hr.; - - Eliminated primarily by biliary and renal excretion. | Treatment of hypertension. May be used alone or in combination with other antihypertensives, such as diuretics and calcium channel blockers. | Initial dose is 600 mg once daily. Can be given once or twice daily with doses ranging 400 mg to 800 mg. | - - When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - Elderly, hepatically impaired, or renally impaired patients should not exceed 600 mg daily.
Irbesartan (Avapro^®^) | - - After oral administration, peak plasma concentrations reached at 1.5–2 hr.; - - Average terminal elimination of half-life is 11–15 hr.; - - Eliminated primarily by biliary and renal excretion. | 1. Treatment of hypertension. May be used alone or with other antihypertensive agents.; 2. Nephropathy in type 2 diabetic patients. Indicated for treatment of patients with an elevated serum creatinine and proteinuria > 300 mg/day). Reduces rate of progression of nephropathy. | Initial dose is 150 mg once daily. Patients who require more reduction in BP should be titrated to 300 mg once daily. | - - When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - Nephropathy in type 2 diabetic patients: maintenance dose is 300 mg once daily.; - - Children (6–12 years): initial dose of 75 mg, up to 150 mg once daily. Ages 13–16: initial 150 mg once daily, can be titrated to 300 mg once daily, higher doses not recommended.; - - Lower initial dose for patients with depletion of intravascular volume or salt.
Losartan (Cozaar^®^) | - - After oral administration, mean peak concentrations reached in 1 hr.; - - Terminal half-life is 2 hr.; - - Eliminated primarily by biliary and renal excretion. | 1. Treatment of hypertension. May be used alone or with other antihypertensive agents, including diuretics.; 2. Hypertensive patients with LV hypertrophy: reduces risk of stroke, though some evidence that this does not apply to black patients.; 3. Nephropathy in type 2 diabetic patients: reduces rate of progression of nephropathy as measured by doubling of serum creatinine or end-stage renal disease. | Initial dose is 50 mg once daily, with 25 mg used in patients with possible depletion of intravascular volume and patients with history of hepatic impairment. May be given twice daily with total doses from 25 mg to 100 mg. | - - When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - Pediatric hypertensive patients (6 years and greater): starting dose is 0.7 mg/kg once daily (up to 50 mg total) given as tablet or a suspension.; - - Hypertensive patients with LV hypertrophy: starting dose is 50 mg once daily. Based on BP response, hydrochlorothiazide 12.5 mg daily should be added and/or dose of losartan should be increased to 100 mg once daily followed by an increase of hydrochlorothiazide to 25 mg once daily.
Olmesartan medoxomil (Benicar^®^) | - - After oral administration, peak plasma concentrations reached after 1–2 hr.; - - Terminal elimination of half-life is 13 hr.; - - Eliminated primarily by biliary and renal excretion. | Treatment of hypertension. May be used alone or with other antihypertensive agents. | Initial dose is 20 mg once daily. For patients requiring further reduction in BP, dose may be increased to 40 mg. | When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - In patients with impaired renal failure, a lower starting dose should be considered.
Telmisartan (Micardis^®^) | - - After oral administration, peak concentrations reached within 0.5–1 hr.; - - Terminal elimination of half-life is 24 hr.; - - Eliminated mostly through feces. | Treatment of hypertension. May be used alone or with other antihypertensive agents. | Starting dose is 40 mg once daily. BP response is dose-related over range of 20–80 mg. | - - When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - Patients with depletion of intravascular volume, biliary obstructive disorders, or hepatic insufficiency should start treatment under close medical supervision.
Valsartan (Diovan^®^) | - - After oral administration, peak plasma concentrations reached within 2–4 hr.; - - Average elimination half-life about 6 hr.; - - Primarily eliminated in feces and urine. | 1. Treatment of hypertension. May be used alone or with other antihypertensive agents.; 2. Heart failure: used in treatment of heart failure, reduces hospitalizations.; 3. Post-MI: used to reduce cardiovascular mortality. | Initial dose is 80 mg or 160 mg once daily in patients who are not volume depleted. May be used over a dose range of 80 mg to 320 mg once daily. | - - When used in pregnancy during the second and third trimesters, drugs that act directly on the rennin- angiotensin system can cause injury and even death to the developing fetus.; - - Care should be given when dosing patients with hepatic or severe renal impairment.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); hr = hour(s); LV = left ventricular; MI = myocardial infarction

Studies with treatment protocols that permitted the addition of other antihypertensive medications during the trial if certain blood pressure targets were not met were included provided the cointervention protocols were the same in both groups.

### Outcomes of Interest

We considered a wide range of outcomes pertaining to the long-term benefits and harms of ACEIs versus ARBs. These are listed above in the section on “Scope and Key Questions.” In somewhat greater detail, and in order of relative priority, these outcomes were:

- Blood pressure control (we preferred seated trough blood pressure, where reported).
- Mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific).
- Morbidity (especially major cardiovascular events [MI, stroke] and measures of quality of life).
- Safety (focusing on serious adverse event rates, overall adverse event rates, and withdrawals due to adverse events).
- Specific adverse events (including, but not limited to, cough and angioedema).
- Persistence/adherence.
- Rate of use of a single antihypertensive for blood pressure control.
- Other intermediate outcomes:
  - Lipid levels (high-density lipoprotein [HDL], low-density lipoprotein [LDL], total cholesterol [TC], and triglyceride [TG]).
  - Rates of progression to type 2 diabetes.
  - Markers of carbohydrate metabolism/diabetes control (glycated hemoglobin [HbA1c], insulin or other diabetes medication dosage, fasting plasma glucose, or aggregated measures of serial glucose measurements).
  - Measures of LV mass/function (left ventricular mass index [LVMI] and ejection fraction [LVEF]).
  - Measures of kidney disease (creatinine/glomerular filtration rate [GFR], proteinuria).

The key questions ask about the comparative long-term benefits and harms of ACEIs versus ARBs for treating essential hypertension, but do not define precisely what is meant by “long-term.” We initially interpreted this to mean 6 months or longer, but decided after the abstract screening to reduce this to 12 weeks or longer. We made this decision for two reasons: (1) the distribution of length of followup was highly skewed toward shorter duration, so that a longer threshold would have excluded nearly all head-to-head studies of ACEIs and ARBs; (2) a strong differential benefit or harm detected in a short-duration study could be important to identify, especially if similar effects were suggested, perhaps less strongly, by longer-term studies.

### Types of Studies

We included comparative clinical studies of any design, including randomized controlled trials (RCTs), nonrandomized controlled clinical trials, retrospective and prospective cohort studies, and case-control studies.

We excluded studies with fewer than 20 total patients in the ACEI and ARB treatment arms.

## Data Extraction

We developed a data abstraction form/evidence table template for abstracting data from the included studies (Appendix D) and used the same form for all study designs and to capture data relevant to all three key questions. Abstractors worked in pairs: the first abstracted the data, and the second over-read the article and the accompanying abstraction to check for accuracy and completeness. The completed evidence table is provided in Appendix E.

We extracted the following data from included trials: geographical location; funding source; study design; interventions (including dose, duration, dose titration protocol [if any], and cointerventions [if any]); population characteristics (including age, sex, race/ethnicity, baseline blood pressure, concurrent medications, and comorbidities); recruitment setting; inclusion and exclusion criteria; numbers screened, eligible, enrolled, and lost to followup; and results for each outcome.

## Quality Assessment

We used predefined criteria to assess the quality of individual controlled trials and prospective or retrospective observational (cohort) studies. To assess the quality of clinical trials and cohort studies, we adapted criteria developed by the U.S. Preventive Services Task Force (USPSTF) and the CRD.7,8

Individual studies were graded as “good,” “fair,” or “poor” in quality according to the following definitions:

A “good” study has the least bias and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.

A “fair” study is susceptible to some bias, but probably not sufficient to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.

A “poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

If a study was rated as fair or poor, assessors were instructed to note important limitations on internal validity based on the USPSTF/CRD criteria, as adapted here:

1. Initial assembly of comparable groups:
  - - For RCTs: Adequate randomization, including concealment and whether potential confounders were distributed equally among groups.
  - - For cohort studies: Consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
2. Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination).
3. Important differential loss to followup or overall high loss to followup.
4. Measurements: Equal, reliable, and valid (includes masking of outcome assessment).
5. Clear definition of interventions.
6. All important outcomes considered.
7. Analysis: Adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs.

Assessment of each study’s quality was made by a single rater and then evaluated by a second rater. Finally, quality assessments were reviewed across studies. Disagreements were resolved by consensus. Final quality assessments for individual studies are included in the evidence table (Appendix E).

## Applicability

We did not provide a global rating of applicability (such as “high” or “low”) because applicability may differ substantially based on the user of this report. However, applicability of research studies was assessed by noting the most important potential limitations in a study’s applicability from among the list described by Rothwell.9 These criteria, slightly adapted by the SRC, are reproduced in Appendix F. Assessors were instructed to list the most important (up to three) limitations affecting applicability, if any, based on this list.

Throughout this report, we highlight effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. The results of effectiveness studies are more applicable to the spectrum of patients that will use a drug, have a test, or undergo a procedure than results from highly selected populations in efficacy studies.

## Rating the Body of Evidence

We assessed the strength of the body of evidence for each key question using the GRADE framework.10 In rating the strength of evidence we considered the number of studies, the size of the studies, strength of study design, and the quality of individual studies. In addition, as part of the GRADE framework, we assessed the consistency across studies of the same design, consistency across different study designs, the magnitude of effect, and applicability. Finally, if applicable, we considered the likelihood of publication bias and (especially for observational studies) the potential influence of plausible confounders. We commented specifically when it was difficult or impossible to assess certain of these dimensions. The overall strength of a given body of evidence was rated qualitatively using the following four-level scale:

High – Further research is very unlikely to change our confidence in the estimate of effect.

Moderate – Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

Low – Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Very low – Any estimate of effect is very uncertain.

## Data Synthesis

Given that many studies did not have the statistical power to determine equivalence for the outcomes relevant to this review (which were often not the primary outcomes evaluated by study investigators), we considered pooling in an attempt to overcome the type II error.

In evaluating groups of studies reporting the same or similar outcomes for potential data synthesis, we primarily considered clinical homogeneity. In this assessment, we tended to be inclusive of individual studies unless their populations were clearly dissimilar (e.g., when considering renal outcomes we chose to exclude from pooled analysis studies of patients with renal failure). We considered groups of studies to be suitable candidates for a quantitative synthesis when we were able to identify at least four clinically relatively similar studies that assessed the same outcome (e.g., when considering effects on lipids, we chose not to pool, as the group included different lipid measures.) While not proof of the validity of this approach, it is notable that there were no situations in which pooled estimates of relative efficacy regarding a particular outcome were contrary to the global impression of the reviewers.

When we calculated summary effect sizes, we stratified these by study design, separating RCTs from observational studies. We used Comprehensive Meta-analysis Version 2 (Borenstein M, Hedges L, Higgins J, Rothstein H. Comprehensive Meta-analysis Version 2, Biostat, Englewood NJ [2005]) to test for heterogeneity and to pool (while recognizing that the ability of statistical methods to detect heterogeneity is limited, particularly when the number of studies is small). In the presence of statistical heterogeneity, we evaluated likely explanatory clinical and methodological study characteristics to determine whether they could explain the heterogeneity observed. If, after this further scrutiny, studies appeared to be clinically and methodologically similar, we performed pooling even in the presence of statistical heterogeneity. Pooled estimates combining both study designs were also calculated in order to estimate confidence limits for an overall effect.

When pooling was performed, we used the random-effects model for the primary analysis; in addition, we present summary estimates derived using the fixed-effect model as a sensitivity analysis. Furthermore, for count outcomes, we calculated a summary of the relative effect (odds ratio) and absolute effect (risk difference). When the results from statistical testing were similar, we present the outcome that we judged to be most clinically relevant. We also present the number-needed-to-treat (NNT) when effects are statistically significant. In calculating the NNT, we used either the inverse of the risk difference (when risk difference is presented as the pooling measure), or the inverse of an estimated difference based on an average control event rate and a relative measure of effect (when odds ratio is used as the measure for pooling).

Given the dearth of studies of the same ACEI versus ARB comparison, and the presumed general similarity of each class, when studies were combined, pooling was performed without regard to the specific drug within the ACEI or ARB class. Also, we did not specifically consider study design in deciding whether to pool, but when we did pool, we stratified the analysis to examine differences between observational studies and randomized controlled trials, as described above.

In deciding whether to pool indirect comparison studies, we adopted a similar approach. However, given the more tenuous nature of indirect comparisons, we used specific quantitative criteria for pooling (see Appendix B).