# Introduction

## Background

More than 65 million American adults (one-third) have hypertension. The prevalence of hypertension increases with advancing age such that more than half of people 60 to 69 years of age and approximately three-fourths of those 70 years of age and older are affected.1 Furthermore, increasing prevalence of obesity may further increase the prevalence of hypertension in the United States. According to estimates from the World Health Organization, worldwide prevalence estimates for hypertension may be as much as 1 billion individuals, and suboptimal blood pressure is the number one attributable risk factor for death throughout the world.2 Substantial excess morbidity also occurs when hypertension affects numerous target organs including the brain, eyes, heart, arteries, and kidneys.

Despite the high morbidity and mortality attributable to hypertension, control remains suboptimal. Approximately one-third of adults remain unaware of their hypertension, over 40 percent of individuals with hypertension are not on treatment, and two-thirds of hypertensive patients continue to have blood pressures above even modest treatment goals (< 140/90 mmHg).3 Several nonpharmacological interventions – including diet, exercise, and control of body weight – are effective in lowering blood pressure; however, such therapies are often insufficient or not sustained, resulting in reliance on pharmacotherapy. Various classes of antihypertensive drug treatments are available, but determining their comparative effectiveness is complicated. Therapeutic choices may be influenced by patient characteristics – including comorbidities and race – that also affect the risk of certain clinical end points. Multi-drug therapy is often required to achieve satisfactory control, leading to greater variables to consider in treatment choices.3 Finally, adverse events that are characteristic of the individual agents or drug classes further complicate therapeutic decisionmaking.

The renin-angiotensin-aldosterone (renin) system is an important mediator of blood volume, arterial pressure, and cardiac and vascular function. Components of this system can be identified in many tissues. The primary site of renin release is the kidney, and release is triggered by sympathetic stimulation, renal artery hypotension, and decreased sodium delivery to the distal tubule. Via proteolytic cleavage, renin acts on the oligopeptide substrate, angiotensinogen, to produce the decapeptide angiotensin I. In turn, two terminal peptide residues of angiotensin I are removed by the angiotensin-converting enzyme (ACE) to form the octapeptide angiotensin II. Angiotensin II acts directly on the resistance vessels to increase systemic vascular resistance and arterial pressure; stimulates the adrenal cortex to release aldosterone, leading to increased sodium and water reabsorption and potassium excretion; promotes secretion of antidiuretic hormone, leading to fluid retention; stimulates thirst; promotes adrenergic function; and increases cardiac and vascular hypertrophy.

Therapies aimed at modifying the renin system have been used extensively for treatment of hypertension, heart failure, myocardial infarction (MI), diabetes, and renal disease.4,5 Currently, therapies fall into one of two classes of angiotensin antagonists: the angiotensin-converting enzyme inhibitors (ACEIs), and the angiotensin II receptor antagonists (ARBs or angiotensin receptor blockers). ACEIs block conversion of angiotensin I to angiotensin II. ARBs selectively inhibit angiotensin II from activating the angiotensin specific receptor (AT_1_).

While ACEIs and ARBs both target the renin system and are regarded by clinicians as effectively equivalent, it is not clear that this is appropriate. ACEIs, for example, do not entirely block production of angiotensin II due to the presence of unaffected converting enzymes. Also, ACEIs are associated with well-known adverse events not shared by ARBs, including cough (estimated incidence 5 to 20 percent) and the possibly related phenomenon of angioedema (estimated incidence 0.1 to 0.2 percent).6 Further, distinguishing effectiveness between these two groups of commonly used angiotensin antagonists is particularly problematic. Although both ACEIs and ARBs are highly effective in lowering blood pressure among patients with essential hypertension,4,5 the comparative effectiveness of the ACEIs and ARBs is not known. In addition, because many patients with hypertension require multiple medications to achieve adequate blood pressure control, angiotensin antagonists are often optimal second-line antihypertensive drugs. However, the relative advantages and disadvantages of ACEIs versus ARBs are not well known despite several studies that have compared the effectiveness within other classes of antihypertensive drugs as well as recent drug class reviews for ACEIs4 and ARBs.5

In this comparative effectiveness review, we examine the scientific literature on ACEIs and ARBs for individuals with hypertension regarding their relative benefits (blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes), as well as relative risks (safety, adverse events, tolerability, persistence, and adherence). In addition, we will examine the clinical determinants of these outcomes with a focus on the long-term impact.

## Scope and Key Questions

This review summarizes the evidence on the comparative long-term benefits and harms of ACEIs versus ARBs for treating essential hypertension in adults. Key questions addressed are:

Key Question 1. For adult patients^a^ with essential hypertension, how do ACEIs (angiotensin-converting enzyme inhibitors) and ARBs (angiotensin II receptor antagonists)^b^ differ in blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes^c^?

a “Adult patients” are defined as adults, age 18 years or older.

b Table 1 lists the specific ACEIs and ARBs evaluated in this review and describes their characteristics and current indications.

c Outcomes considered include:

Intermediate outcomes: Blood pressure control; rate of use of a single antihypertensive agent for blood pressure control; lipid levels; progression to type 2 diabetes; markers of carbohydrate metabolism/diabetes control; measures of left ventricular (LV) mass/function; and measures of kidney disease.

Health outcomes: Mortality (all-cause mortality, cardiovascular disease-specific mortality, and cerebrovascular disease-specific mortality); and morbidity (cardiac events [myocardial infarction], heart failure, cerebral vascular disease or events [including stroke], symptomatic coronary artery disease, end-stage renal disease, peripheral vascular disease, and quality of life).

Key Question 2. For adult patients with essential hypertension, how do ACEIs and ARBs differ in safety,^d^ adverse events,^e^ tolerability, persistence, and adherence?

d Safety outcomes: Overall adverse events, withdrawals due to adverse events, serious adverse events reported, withdrawal rates, and switch rates. (For practical reasons, we separate safety/adverse events and tolerability/persistence [including switch rates], as the latter may or may not be due to identifiable adverse events.)

e Specific adverse events: These included, but were no limited to, cough and angioedema.

Key Question 3. Are there subgroups of patients based on demographic characteristics (age, racial and ethnic groups, sex), use of other medications concurrently, or comorbidities for which ACEIs or ARBs are more effective, associated with fewer adverse events, or better tolerated?