# List of Excluded Direct Comparator Studies

All studies listed below were either identified at the abstract screening stage as having treatment duration/length of followup less than 12 weeks or were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Akinboboye OO, Chou RL, Bergmann SR. Augmentation of myocardial blood flow in hypertensive heart disease by angiotensin antagonists: a comparison of lisinopril and losartan. J Am Coll Cardiol 2002;40(4):703–9. Exclude: N < 20.

Alcocer L, Fernandez-Bonetti P, Campos E, et al. Clinical efficacy and safety of telmisartan 80 mg once daily compared with enalapril 20 mg once daily in patients with mild-to-moderate hypertension: results of a multicentre study. Int J Clin Pract Suppl 2004;(145):23–8. Exclude: Followup < 12 wk.

Almazov VA, Shlyakhto EV, Konrady AO, et al. Correction of hypertensive cardiac remodelling: comparison of different antihypertensive therapies. Med Sci Monit 2000;6(2):309–13. Exclude: N < 20.

Altiparmak MR, Trablus S, Apaydin S, et al. Is losartan as effective as enalapril on posttransplant persistent proteinuria? Transplant Proc 2001;33(7–8):3368–9. Exclude: Not essential hypertension.

Andersen S, Tarnow L, Rossing P, et al. Renoprotective effects of angiotensin II receptor blockade in type 1 diabetic patients with diabetic nephropathy. Kidney Int 2000;57(2):601–6. Exclude: Followup < 12 wk.

Azizi M, Linhart A, Alexander J, et al. Pilot study of combined blockade of the renin-angiotensin system in essential hypertensive patients. J Hypertens 2000;18(8):1139–47. Exclude: Followup < 12 wk.

Bakris G, Sica D, Ram V, et al. A comparative trial of controlled-onset, extended-release verapamil, enalapril, and losartan on blood pressure and heart rate changes. Am J Hypertens 2002;15(1 Pt 1):53–7. Exclude: Followup < 12 wk.

Bavanandan S, Morad Z, Ismail O, et al. A comparison of valsartan and perindopril in the treatment of essential hypertension in the Malaysian population. Med J Malaysia 2005;60(2):158–62. Exclude: Followup < 12 wk.

Benz J, Oshrain C, Henry D, et al. Valsartan, a new angiotensin II receptor antagonist: a double-blind study comparing the incidence of cough with lisinopril and hydrochlorothiazide. J Clin Pharmacol 1997;37(2):101–7. Exclude: Followup < 12 wk.

Botero R, Matiz H, Maria E, et al. Efficacy and safety of valsartan compared with enalapril at different altitudes. Int J Cardiol 2000;72(3):247–54. Exclude: Followup < 12 wk.

Brown NJ, Kumar S, Painter CA, et al. ACE inhibition versus angiotensin type 1 receptor antagonism: differential effects on PAI-1 over time. Hypertension 2002;40(6):859–65. Exclude: Followup < 12 wk.

Byyny RL, Merrill DD, Bradstreet TE, et al. An inpatient trial of the safety and efficacy of losartan compared with placebo and enalapril in patients with essential hypertension. Cardiovasc Drugs Ther 1996;10(3):313–9. Exclude: Followup < 12 wk.

Cha YJ, Pearson VE. Angioedema due to losartan. Ann Pharmacother 1999;33(9):936–8. Exclude: Followup < 12 wk.

Chan P, Tomlinson B, Huang TY, et al. Double-blind comparison of losartan, lisinopril, and metolazone in elderly hypertensive patients with previous angiotensin-converting enzyme inhibitor-induced cough. J Clin Pharmacol 1997;37(3):253–7. Exclude: Followup < 12 wk.

Chanudet X, De Champvallins M. Antihypertensive efficacy and tolerability of low-dose perindopril/indapamide combination compared with losartan in the treatment of essential hypertension. Int J Clin Pract 2001;55(4):233–9. Exclude: Not ACEI vs. ARB.

Chen JH, Cheng JJ, Chen CY, et al. Comparison of the efficacy and tolerability of telmisartan 40 mg vs. enalapril 10 mg in the treatment of mild-to-moderate hypertension: a multicentre, double-blind study in Taiwanese patients. Int J Clin Pract Suppl 2004;(145):29–34. Exclude: Followup < 12 wk.

Chen K, Chiou CF, Plauschinat CA, et al. Patient satisfaction with antihypertensive therapy. J Hum Hypertens 2005;19(10):793–9. Exclude: Followup < 12 wk.

Cheung R, Lewanczuk RZ, Rodger NW, et al. The effect of valsartan and captopril on lipid parameters in patients with type II diabetes mellitus and nephropathy. Int J Clin Pract 1999;53(8):584–92. Exclude: No separate results for subgroup with hypertension.

Chiou KR, Chen CH, Ding PY, et al. Randomized, double-blind comparison of irbesartan and enalapril for treatment of mild to moderate hypertension. Chung Hua I Hsueh Tsa Chih 2000;63(5):368–76. Exclude: Followup < 12 wk.

Chowta KN, Chowta MN, Bhat P, et al. An open comparative clinical trial to assess the efficacy and safety of losartan versus enalapril in mild to moderate hypertension. J Assoc Physicians India 2002;50:1236–9. Exclude: Followup < 12 wk.

Critchley JA, Gilchrist N, Ikeda L, et al. A randomized, double-masked comparison of the antihypertensive efficacy and safety of combination therapy with losartan and hydrochlorothiazide versus captopril and hydrochlorothiazide in elderly and younger patients. Curr Ther Res Clin Exp 1996;57(5):392–407. Exclude: Could not obtain copy.

Cuocolo A, Storto G, Izzo R, et al. Effects of valsartan on left ventricular diastolic function in patients with mild or moderate essential hypertension: comparison with enalapril. J Hypertens 1999;17(12 Pt 1):1759–66. Exclude: Followup < 12 wk.

de la Sierra A, Gil-Extremera B, Calvo C, et al. Comparison of the antihypertensive effects of the fixed dose combination enalapril 10 mg/nitrendipine 20 mg vs losartan 50 mg/hydrochlorothiazide 12.5 mg, assessed by 24-h ambulatory blood pressure monitoring, in essential hypertensive patients. J Hum Hypertens 2004;18(3):215–22. Exclude: Followup < 12 wk.

Delles C, Jacobi J, John S, et al. Effects of enalapril and eprosartan on the renal vascular nitric oxide system in human essential hypertension. Kidney Int 2002;61(4):1462–8. Exclude: Followup < 12 wk.

Delles C, Schneider MP, John S, et al. Angiotensin converting enzyme inhibition and angiotensin II AT1-receptor blockade reduce the levels of asymmetrical N(G), N(G)-dimethylarginine in human essential hypertension. Am J Hypertens 2002;15(7 Pt 1):590–3. Exclude: Followup < 12 wk.

Diamond JA, Gharavi A, Roychoudhury D, et al. Effect of long-term eprosartan versus enalapril antihypertensive therapy on left ventricular mass and coronary flow reserve in stage I-II hypertension. Eprosartan Study Group. Curr Med Res Opin 1999;15(1):1–8. Exclude: Could not obtain copy.

Donmez G, Derici U, Erbas D, et al. The effects of losartan and enalapril therapies on the levels of nitric oxide, malondialdehyde, and glutathione in patients with essential hypertension. Jpn J Physiol 2002;52(5):435–40. Exclude: Followup < 12 wk.

el-Agroudy AE, Hassan NA, Foda MA, et al. Effect of angiotensin II receptor blocker on plasma levels of TGF-beta 1 and interstitial fibrosis in hypertensive kidney transplant patients. Am J Nephrol 2003;23(5):300–6. Exclude: Not essential hypertension.

Erdem Y, Usalan C, Haznedaroglu IC, et al. Effects of angiotensin converting enzyme and angiotensin II receptor inhibition on impaired fibrinolysis in systemic hypertension. Am J Hypertens 1999;12(11 Pt 1):1071–6. Exclude: No outcomes of interest.

Erley CM, Bader B, Scheu M, et al. Renal hemodynamics in essential hypertensives treated with losartan. Clin Nephrol 1995;43 Suppl 1:S8–11. Exclude: Followup < 12 wk.

Fagard R, Lijnen P, Pardaens K, et al. A randomised, placebo-controlled, double-blind, crossover study of losartan and enalapril in patients with essential hypertension. J Hum Hypertens 2001;15(3):161–7. Exclude: Followup < 12 wk.

Fogari R, Zoppi A, Carretta R, et al. Effect of indomethacin on the antihypertensive efficacy of valsartan and lisinopril: a multicentre study. J Hypertens 2002;20(5):1007–14. Exclude: Followup < 12 wk.

Fogari R, Zoppi A, Corradi L, et al. Comparative effects of lisinopril and losartan on insulin sensitivity in the treatment of non diabetic hypertensive patients. Br J Clin Pharmacol 1998;46(5):467–71. Exclude: Followup < 12 wk.

Fogari R, Zoppi A, Lazzari P, et al. ACE inhibition but not angiotensin II antagonism reduces plasma fibrinogen and insulin resistance in overweight hypertensive patients. J Cardiovasc Pharmacol 1998;32(4):616–20. Exclude: Followup < 12 wk.

Fox JC, Leight K, Sutradhar SC, et al. The JNC 7 approach compared to conventional treatment in diabetic patients with hypertension: a double-blind trial of initial monotherapy vs. combination therapy. J Clin Hypertens (Greenwich) 2004;6(8):437–42; quiz 443–4. Exclude: Followup < 12 wk.

Franchi F, Lazzeri C, Foschi M, et al. Cardiac autonomic tone during trandolapril-irbesartan low-dose combined therapy in hypertension: a pilot project. J Hum Hypertens 2002;16(8):597–604. Exclude: Followup < 12 wk.

Gainer JV, Morrow JD, Loveland A, et al. Effect of bradykinin-receptor blockade on the response to angiotensin-converting-enzyme inhibitor in normotensive and hypertensive subjects. N Engl J Med 1998;339(18):1285–92. Exclude: Followup < 12 wk.

Gansevoort RT, de Zeeuw D, de Jong PE. Is the antiproteinuric effect of ACE inhibition mediated by interference in the renin-angiotensin system? Kidney Int 1994;45(3):861–7. Exclude: Followup < 12 wk.

Goldberg MR, Bradstreet TE, McWilliams EJ, et al. Biochemical effects of losartan, a nonpeptide angiotensin II receptor antagonist, on the renin-angiotensin-aldosterone system in hypertensive patients. Hypertension 1995;25(1):37–46. Exclude: Followup < 12 wk.

Gradman AH, Arcuri KE, Goldberg AI, et al. A randomized, placebo-controlled, double-blind, parallel study of various doses of losartan potassium compared with enalapril maleate in patients with essential hypertension. Hypertension 1995;25(6):1345–50. Exclude: Followup < 12 wk.

Guasti L, Petrozzino MR, Mainardi LT, et al. Autonomic function and baroreflex sensitivity during angiotensin-converting enzyme inhibition or angiotensin II AT-1 receptor blockade in essential hypertensive patients. Acta Cardiol 2001;56(5):289–95. Exclude: Followup < 12 wk.

Guasti L, Zanotta D, Diolisi A, et al. Changes in pain perception during treatment with angiotensin converting enzyme-inhibitors and angiotensin II type 1 receptor blockade. J Hypertens 2002;20(3):485–91. Exclude: Followup < 12 wk.

Hannedouche T, Chanard J, Baumelou B, et al. Evaluation of the safety and efficacy of telmisartan and enalapril, with the potential addition of frusemide, in moderate-renal failure patients with mild-to-moderate hypertension. J Renin Angiotensin Aldosterone Syst 2001;2(4):246–54. Exclude: Followup < 12 wk.

Hasler C, Nussberger J, Maillard M, et al. Sustained 24-hour blockade of the renin-angiotensin system: a high dose of a long-acting blocker is as effective as a lower dose combined with an angiotensin-converting enzyme inhibitor. Clin Pharmacol Ther 2005;78(5):501–7. Exclude: Followup < 12 wk.

Hedner T, Oparil S, Rasmussen K, et al. A comparison of the angiotensin II antagonists valsartan and losartan in the treatment of essential hypertension. Am J Hypertens 1999;12(4 Pt 1):414–7. Exclude: Followup < 12 wk.

Himmelmann A, Keinanen-Kiukaanniemi S, Wester A, et al. The effect duration of candesartan cilexetil once daily, in comparison with enalapril once daily, in patients with mild to moderate hypertension. Blood Press 2001;10(1):43–51. Exclude: Followup < 12 wk.

Holwerda NJ, Fogari R, Angeli P, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy and safety compared with placebo and enalapril. J Hypertens 1996;14(9):1147–51. Exclude: Followup < 12 wk.

Hong L, Maoyin C, Ping C, et al. Comparison of losartan and benazepril for the treatment of mild and moderate essential hypertension. Acta Academiae Medicinae Hubei 2000;21(3):211–3. Exclude: Followup < 12 wk.

Iimura O, Shimamoto K, Matsuda K, et al. Effects of angiotensin receptor antagonist and angiotensin converting enzyme inhibitor on insulin sensitivity in fructose-fed hypertensive rats and essential hypertensives. Am J Hypertens 1995;8(4 Pt 1):353–7. Exclude: Followup < 12 wk.

Ito A, Egashira K, Narishige T, et al. Renin-angiotensin system is involved in the mechanism of increased serum asymmetric dimethylarginine in essential hypertension. Jpn Circ J 2001;65(9):775–8. Exclude: Followup < 12 wk.

Jilma B, Li-Saw-Hee FL, Wagner OF, et al. Effects of enalapril and losartan on circulating adhesion molecules and monocyte chemotactic protein-1. Clin Sci (Colch) 2002;103(2):131–6. Exclude: Followup < 12 wk.

Joshi SR, Yeolekar ME, Tripathi KK, et al. Evaluation of efficacy and tolerability of Losartan and Ramipril combination in the management of hypertensive patients with associated diabetes mellitus in India (LORD Trial). J Assoc Physicians India 2004;52:189–95. Exclude: Not ACEI vs. ARB.

Karas M, Lacourciere Y, LeBlanc AR, et al. Effect of the renin-angiotensin system or calcium channel blockade on the circadian variation of heart rate variability, blood pressure and circulating catecholamines in hypertensive patients. J Hypertens 2005;23(6):1251–60. Exclude: Followup < 12 wk.

Kim W, Lee S, Kang SK, et al. Effects of angiotensin converting enzyme inhibitor and angiotensin II receptor antagonist therapy in hypertensive renal transplant recipients. Transplant Proc 2002;34(8):3223–4. Exclude: Followup < 12 wk.

Klein IH, Ligtenberg G, Oey PL, et al. Enalapril and losartan reduce sympathetic hyperactivity in patients with chronic renal failure. J Am Soc Nephrol 2003;14(2):425–30. Exclude: Followup < 12 wk.

Kraiczi H, Hedner J, Peker Y, et al. Comparison of atenolol, amlodipine, enalapril, hydrochlorothiazide, and losartan for antihypertensive treatment in patients with obstructive sleep apnea. Am J Respir Crit Care Med 2000;161(5):1423–8. Exclude: Followup < 12 wk.

Lacourciere Y. The incidence of cough: a comparison of lisinopril, placebo and telmisartan, a novel angiotensin II antagonist. Telmisartan Cough Study Group. Int J Clin Pract 1999;53(2):99–103. Exclude: Followup < 12 wk.

Lacourciere Y. A multicenter, randomized, double-blind study of the antihypertensive efficacy and tolerability of irbesartan in patients aged > or = 65 years with mild to moderate hypertension. Clin Ther 2000;22(10):1213–24. Exclude: Followup < 12 wk.

Lacourciere Y, Brunner H, Irwin R, et al. Effects of modulators of the renin-angiotensin-aldosterone system on cough. Losartan Cough Study Group. J Hypertens 1994;12(12):1387–93. Exclude: Followup < 12 wk.

Lacourciere Y, Lefebvre J. Modulation of the renin-angiotensin-aldosterone system and cough. Can J Cardiol 1995;11 Suppl F:33F–9F. Exclude: Followup < 12 wk.

Lee C-M, Lee Y-T, Lang MG, et al. A comparison of valsartan and captopril in Taiwanese patients with essential hypertension. Adv Ther 1999;16(1):39–48. Exclude: Followup < 12 wk.

Lee YJ, Chiang YF, Tsai JC. Severe nonproductive cough and cough-induced stress urinary incontinence in diabetic postmenopausal women treated with ACE inhibitor. Diabetes Care 2000;23(3):427–8. Exclude: Followup < 12 wk.

Leu HB, Charng MJ, Ding PY. A double blind randomized trial to compare the effects of eprosartan and enalapril on blood pressure, platelets, and endothelium function in patients with essential hypertension. Jpn Heart J 2004;45(4):623–35. Exclude: Followup < 12 wk.

Li-Saw-Hee FL, Beevers DG, Lip GY. Effect of antihypertensive therapy using enalapril or losartan on haemostatic markers in essential hypertension: a pilot prospective randomised double-blind parallel group trial. Int J Cardiol 2001;78(3):241–6. Exclude: Followup < 12 wk.

Mahmud A, Feely J. Favourable effects on arterial wave reflection and pulse pressure amplification of adding angiotensin II receptor blockade in resistant hypertension. J Hum Hypertens 2000;14(9):541–6. Exclude: Followup < 12 wk.

Mahmud A, Feely J. Reduction in arterial stiffness with angiotensin II antagonist is comparable with and additive to ACE inhibition. Am J Hypertens 2002;15(4 Pt 1):321–5. Exclude: Followup < 12 wk.

Mallion J-M, Boutelant S, Chabaux P, et al. Valsartan, a new angiotensin II antagonist blood pressure reduction in essential hypertension compared with an angiotensin converting enzyme inhibitor, enalapril. Blood Press Monit 1997;2(3–4):179–84. Exclude: Could not obtain copy.

Matsumoto T, Minai K, Horie H, et al. Angiotensin-converting enzyme inhibition but not angiotensin II type 1 receptor antagonism augments coronary release of tissue plasminogen activator in hypertensive patients. J Am Coll Cardiol 2003;41(8):1373–9. Exclude: Followup < 12 wk.

Morgan T, Anderson A. Low-dose combination therapy with perindopril and indapamide compared with irbesartan. Clinical Drug Investigation 2002;22(8):553–60. Exclude: Not ACEI vs. ARB.

Morgan T, Anderson A, Bertram D, et al. Effect of candesartan and lisinopril alone and in combination on blood pressure and microalbuminuria. J Renin Angiotensin Aldosterone Syst 2004;5(2):64–71. Exclude: Followup < 12 wk.

Mourad JJ, Waeber B, Zannad F, et al. Comparison of different therapeutic strategies in hypertension: a low-dose combination of perindopril/indapamide versus a sequential monotherapy or a stepped-care approach. J Hypertens 2004;22(12):2379–86. Exclude: Not ACEI vs. ARB.

Mugellini A, Preti P, Zoppi A, et al. Effect of delapril-manidipine combination vs irbesartan-hydrochlorothiazide combination on fibrinolytic function in hypertensive patients with type II diabetes mellitus. J Hum Hypertens 2004;18(10):687–91. Exclude: Not ACEI vs. ARB.

Mulatero P, Rabbia F, Milan A, et al. Drug effects on aldosterone/plasma renin activity ratio in primary aldosteronism. Hypertension 2002;40(6):897–902. Exclude: Followup < 12 wk.

Nagano M, Higaki J, Mikami H, et al. Role of the renin-angiotensin system in hypertension in the elderly. Blood Press Suppl 1994;5:130–3. Exclude: Followup < 12 wk.

Nakamoto H, Kanno Y, Okada H, et al. Erythropoietin resistance in patients on continuous ambulatory peritoneal dialysis. Adv Perit Dial 2004;20:111–6. Exclude: Not essential hypertension.

Nalbantgil S, Yilmaz H, Gurun C, et al. Effects of valsartan and enalapril on regression of left ventricular hypertrophy in patients with mild to moderate hypertension: A randomized, double-blind study. Curr Ther Res Clin Exp 2000;61(6):331–8. Exclude: Could not obtain copy.

Nawarskas JJ, Townsend RR, Cirigliano MD, et al. Effect of aspirin on blood pressure in hypertensive patients taking enalapril or losartan. Am J Hypertens 1999;12(8 Pt 1):784–9. Exclude: N < 20.

Neki NS, Arora P. A comparative evaluation of therapeutic effects of once a day dose of losartan potassium versus enalapril maleate in mild to moderate essential hypertension. J Indian Med Assoc 2001;99(11):640–1. Exclude: Followup < 12 wk.

Neutel JM, Smith DH, Reilly PA. The efficacy and safety of telmisartan compared to enalapril in patients with severe hypertension. Int J Clin Pract 1999;53(3):175–8. Exclude: Followup < 12 wk.

Okuguchi T, Osanai T, Fujiwara N, et al. Effect of losartan on nocturnal blood pressure in patients with stroke: comparison with angiotensin converting enzyme inhibitor. Am J Hypertens 2002;15(11):998–1002. Exclude: Followup < 12 wk.

Oparil S. Eprosartan versus enalapril in hypertensive patients with angiotensin- converting enzyme inhibitor-induced cough. Curr Ther Res Clin Exp 1999;60(1):1–4. Exclude: Followup < 12 wk.

Papademetriou V, Narayan P, Kokkinos P. Angiotensin-converting enzyme inhibitors and angiotensin receptor blockers in African-American patients with hypertension. J Clin Hypertens (Greenwich) 2004;6(6):310–4. Exclude: Followup < 12 wk.

Paster RZ, Snavely DB, Sweet AR, et al. Use of losartan in the treatment of hypertensive patients with a history of cough induced by angiotensin-converting enzyme inhibitors. Clin Ther 1998;20(5):978–89. Exclude: Followup < 12 wk.

Pechere-Bertschi A, Nussberger J, Decosterd L, et al. Renal response to the angiotensin II receptor subtype 1 antagonist irbesartan versus enalapril in hypertensive patients. J Hypertens 1998;16(3):385–93. Exclude: Followup < 12 wk.

Phakdeekitcharoen B, Leelasa-nguan P. Effects of an ACE inhibitor or angiotensin receptor blocker on potassium in CAPD patients. Am J Kidney Dis 2004;44(4):738–46. Exclude: Followup < 12 wk.

Poirier L, de Champlain J, Larochelle P, et al. A comparison of the efficacy and duration of action of telmisartan, amlodipine and ramipril in patients with confirmed ambulatory hypertension. Blood Press Monit 2004;9(5):231–6. Exclude: Followup < 12 wk.

Prabowo P, Arwanto A, Soemantri D, et al. A comparison of valsartan and captopril in patients with essential hypertension in Indonesia. Int J Clin Pract 1999;53(4):268–72. Exclude: Followup < 12 wk.

Preston RA, Baltodano NM, Alonso AB, et al. Comparative effects on dynamic renal potassium excretion of ACE inhibition versus angiotensin receptor blockade in hypertensive patients with type II diabetes mellitus. J Clin Pharmacol 2002;42(7):754–61. Exclude: Followup < 12 wk.

Prikryl P, Cornelissen G, Neubauer J, et al. Chronobiologically explored effects of telmisartan. Clin Exper Hypertens 2005;27(2–3):119–28. Exclude: Followup < 12 wk.

Ragot S, Genes N, Vaur L, et al. Comparison of three blood pressure measurement methods for the evaluation of two antihypertensive drugs: feasibility, agreement, and reproducibility of blood pressure response. Am J Hypertens 2000;13(6 Pt 1):632–9. Exclude: Followup < 12 wk.

Rake EC, Breeze E, Fletcher AE. Quality of life and cough on antihypertensive treatment: a randomised trial of eprosartan, enalapril and placebo. J Hum Hypertens 2001;15(12):863–7. Exclude: Followup < 12 wk.

Ramsay LE, Kirwan BA, for the Telmisartan Study Group (THESI). A comparison of cough in hypertensive patients receiving telmisartan, enalapril, or hydrochlorothiazide. J Hypertens 1998;16 Suppl 2:S241 (Abstract P31.053). Exclude: Followup < 12 wk.

Ramsay LE, Yeo WW. ACE inhibitors, angiotensin II antagonists and cough. The Losartan Cough Study Group. J Hum Hypertens 1995;9 Suppl 5:S51–4. Exclude: Followup < 12 wk.

Rippin J, Bain SC, Barnett AH, et al. Rationale and design of diabetics exposed to telmisartan and enalapril (DETAIL) study. J Diabetes Complications 2002;16(3):195–200. Exclude: Trial methods & design (no published results as of 8 Dec 2006).

Rizzoni D, Porteri E, De Ciuceis C, et al. Effect of treatment with candesartan or enalapril on subcutaneous small artery structure in hypertensive patients with noninsulin-dependent diabetes mellitus. Hypertension 2005;45(4):659–65. Exclude: N < 20.

Schmidt A, Gruber U, Bohmig G, et al. The effect of ACE inhibitor and angiotensin II receptor antagonist therapy on serum uric acid levels and potassium homeostasis in hypertensive renal transplant recipients treated with CsA. Nephrol Dial Transplant 2001;16(5):1034–7. Exclude: Followup < 12 wk.

Scholze J, Stapff M. Start of therapy with the angiotensin II antagonist losartan after immediate switch from pretreatment with an ACE inhibitor. Br J Clin Pharmacol 1998;46(2):169–72. Exclude: Followup < 12 wk.

Schulz E, Bech J, Pedersen EB, et al. Tolerability and antihypertensive efficacy of losartan vs captopril in patients with mild to moderate hypertension and impaired renal function. A randomised, double-blind, parallel study. Clinical Drug Investigation 2000;19(3):183–94. Exclude: Not essential hypertension.

Schulz E, Bech JN, Pedersen EB, et al. A randomized, double-blind, parallel study on the safety and antihypertensive efficacy of losartan compared to captopril in patients with mild to moderate hypertension and impaired renal function. Nephrol Dial Transplant 1999;14 Suppl 4:27–8. Exclude: Not essential hypertension.

Sega R. Efficacy and safety of eprosartan in severe hypertension. Eprosartan Multinational Study Group. Blood Press 1999;8(2):114–21. Exclude: Followup < 12 wk.

Sever PS, Chang CL. Discordant responses to two classes of drugs acting on the renin-angiotensin system. J Renin Angiotensin Aldosterone Syst 2001;2(1):25–30. Exclude: Followup < 12 wk.

Shobha JC, Kumar TR, Raju BS, et al. Evaluation of efficacy and safety of losartan potassium in the treatment of mild to moderate hypertension as compared to enalapril maleate. J Assoc Physicians India 2000;48(5):497–500. Exclude: Followup < 12 wk.

Sleight P. The ONTARGET/TRANSCEND Trial Programme: baseline data. Acta Diabetol 2005;42 Suppl 1:S50–6. Exclude: Baseline data only (no published results as of 8 Dec 2006).

Smith DH, Dubiel R, Jones M. Use of 24-hour ambulatory blood pressure monitoring to assess antihypertensive efficacy: a comparison of olmesartan medoxomil, losartan potassium, valsartan, and irbesartan. Am J Cardiovasc Drugs 2005;5(1):41–50. Exclude: Followup < 12 wk.

Smith DH, Matzek KM, Kempthorne-Rawson J. Dose response and safety of telmisartan in patients with mild to moderate hypertension. J Clin Pharmacol 2000;40(12 Pt 1):1380–90. Exclude: Followup < 12 wk.

Smith DH, Neutel JM, Morgenstern P. Once-daily telmisartan compared with enalapril in the treatment of hypertension. Adv Ther 1998;15:229–40. Exclude: Could not obtain copy.

Stergiou GS, Efstathiou SP, Roussias LG, et al. Blood pressure- and pulse pressure-lowering effects, trough:peak ratio and smoothness index of telmisartan compared with lisinopril. J Cardiovasc Pharmacol 2003;42(4):491–6. Exclude: Followup < 12 wk.

Stergiou GS, Efstathiou SP, Skeva II, et al. Assessment of drug effects on blood pressure and pulse pressure using clinic, home and ambulatory measurements. J Hum Hypertens 2002;16(10):729–35. Exclude: Followup < 12 wk.

Stergiou GS, Skeva II, Baibas NM, et al. Does the antihypertensive response to angiotensin converting enzyme inhibition predict the antihypertensive response to angiotensin receptor antagonism? Am J Hypertens 2001;14(7 Pt 1):688–93. Exclude: Followup < 12 wk.

Stokes GS, Barin ES, Gilfillan KL. Effects of isosorbide mononitrate and AII inhibition on pulse wave reflection in hypertension. Hypertension 2003;41(2):297–301. Exclude: Followup < 12 wk.

Takami T, Shigemasa M. Efficacy of various antihypertensive agents as evaluated by indices of vascular stiffness in elderly hypertensive patients. Hypertens Res 2003;26(8):609–14. Exclude: ACEI not on our list (temocapril).

Tanser PH, Campbell LM, Carranza J, et al. Candesartan cilexetil is not associated with cough in hypertensive patients with enalapril-induced cough. Multicentre Cough Study Group. Am J Hypertens 2000;13(2):214–8. Exclude: Followup < 12 wk.

Tomiyama H, Motobe K, Zaydun G, et al. Insulin sensitivity and endothelial function in hypertension: a comparison of temocapril and candesartan. Am J Hypertens 2005;18(2 Pt 1):178–82. Exclude: Followup < 12 wk.

Totsuka N, Awata N, Takahashi K, et al. A single-center, open-label, randomized, parallel-group study assessing the differences between an angiotensin II receptor antagonist and an angiotensin-converting enzyme inhibitor in hypertensive patients with congestive heart failure: the research for efficacy of angiotensin II receptor antagonist in hypertensive patients with congestive heart failure study. Curr Ther Res Clin Exp 2003;64(2):81–94. Exclude: Could not obtain copy.

Turner CL, Wilkinson IB, Kirkpatrick PJ. Use of antihypertension agents for the suppression of arterial pulse pressure waveforms in patients with intracranial aneurysms. J Neurosurg 2006;104(4):531–6. Exclude: Followup < 12 wk.

Tylicki L, Rutkowski P, Renke M, et al. Renoprotective effect of small doses of losartan and enalapril in patients with primary glomerulonephritis. Short-term observation. Am J Nephrol 2002;22(4):356–62. Exclude: Not essential hypertension.

Van Ampting JMA, Hijmering ML, Beutler JJ, et al. Vascular effects of ACE inhibition independent of the renin-angiotensin system in hypertensive renovascular disease: A randomized, double-blind, crossover trial. Hypertension 2001;37(1):40–5. Exclude: Followup < 12 wk.

Vidt DG, White WB, Ridley E, et al. A forced titration study of antihypertensive efficacy of candesartan cilexetil in comparison to losartan: CLAIM Study II. J Hum Hypertens 2001;15(7):475–80. Exclude: Followup < 12 wk.

Weber MA. The 24-hour blood pressure pattern: does it have implications for morbidity and mortality? Am J Cardiol 2002;89(2A):27A–33A. Exclude: Trial methods & design (no published results as of 8 Dec 2006).

Weir MR, Smith DH, Neutel JM, et al. Valsartan alone or with a diuretic or ACE inhibitor as treatment for African American hypertensives: relation to salt intake. Am J Hypertens 2001;14(7 Pt 1):665–71. Exclude: Not ACEI vs. ARB.

White WB, Sica DA, Calhoun D, et al. Preventing increases in early-morning blood pressure, heart rate, and the rate-pressure product with controlled onset extended release verapamil at bedtime versus enalapril, losartan, and placebo on arising. Am Heart J 2002;144(4):657–65. Exclude: Followup < 12 wk.

Yavuz D, Koc M, Toprak A, et al. Effects of ACE inhibition and AT1-receptor antagonism on endothelial function and insulin sensitivity in essential hypertensive patients. J Renin Angiotensin Aldosterone Syst 2003;4(3):197–203. Exclude: N < 20.

Zanchetti A, Omboni S. Comparison of candesartan versus enalapril in essential hypertension. Italian Candesartan Study Group. Am J Hypertens 2001;14(2):129–34. Exclude: Followup < 12 wk.

Zanchetti A, Omboni S, Di Biagio C. Candesartan cilexetil and enalapril are of equivalent efficacy in patients with mild to moderate hypertension. J Hum Hypertens 1997;11 Suppl 2:S57–9. Exclude: Followup < 12 wk.

Zimmermann M, Unger T. Challenges in improving prognosis and therapy: the Ongoing Telmisartan Alone and in Combination with Ramipril Global End point Trial programme. Expert Opin Pharmacother 2004;5(5):1201–8. Exclude: Trial methods & design (no published results as of 8 Dec 2006).