# Evidence Table

Evidence Table

Direct comparator studies of ACEIs vs. ARBs

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | Comments/quality/applicability
Amerena, Pappas, Ouellet, et al., 2002 #3620 | Geographical location: national, multicenter: Canada (14 sites), Australia (12), Germany (11), Italy (9), Greece (7), Russia (6), Spain (5), Hungary (5), Czech Republic (4), Lithuania (2) Study dates: NR Funding source: NR (one author affiliated with GSK) Interventions: - Telmisartan (40–80 mg) (n = 264) - Enalapril (10–20 mg) (n = 258) Titrated to higher dose if mean DBP > 90 at wk 6 Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes for most outcomes except mean seated trough DBP Was allocation concealment adequate?: NR Baseline/run-in period: 4 wk placebo Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 882 - Randomized: 522 - Began treatment: 522 - Completed treatment: 482 - Withdrawals/losses to followup: 40 patients prematurely discontinued treatment (12 due to AEs, reasons for others NR) and 6 more were excluded from ITT analysis (no on-therapy efficacy data) - ITT population: 516 (522–6 patients with no efficacy data) Age: Mean (SD): 52 ± 9.6 Median: NRD Range: 23 – 77 Sex (n [%]): Female: 184 (36%) Male: 332 (64%) Race/ethnicity (n [%]): White: 503 (97%) Asian + other: 13 (3%) Baseline blood pressure: Seated unblinded trough (24 hr post-dose) SBP and DBP measured using an automated ABPM SpaceLabs 90207 device; mean of 3 measurements used Baseline values: | | | | | 1) Blood pressure: Change from baseline in mean seated trough BP values at 12 wk (mean values NR): | | | | | General comments: - Patients were withdrawn from the study if DBP > 114 or their seated SBP > 200 mmHg at any time Quality assessment: Overall rating: Fair Comments: - Statistically significant endpoint not blinded Applicability: - No comorbidities discussed - No clear idea of recruitment strategy - Run in period on placebo may be selective to patients that got in - No real baseline information on the patients’ other medical issues
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | [underlined: Telmisartan] | [underlined: Enalapril] | | | | Telmisartan (n = 250) | Enalapril (n = 247) | p
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | SBP: | 159.9 ± 12.4 | 157.7 ± 13.2 | | | SBP: | −11.90 | −10.42 | p = ns
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | DBP: | 103.0 ± 6.3 | 101.6 ± 6.1 | | | DBP: | −9.69 | −7.67 | p < 0.02
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | Concurrent medications (n [%]): No other antihypertensives Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age > 18 - Mild to moderate essential HTN, 95 ≤ DBP ≤ 114 (or 104 in German and Czech sites) Exclusion criteria: - Mean SBP ≥ 180 - Secondary HTN - Uncorrected volume or sodium depletion - Severe renal impairment, renal artery stenosis, hepatic impairment, biliary obstructive disorders, electrolyte disturbances, primary aldosteronism, or hereditary fructose intolerance - Known sensitivity to any component of the placebo, telmisartan, or enalapril tablets - Pregnant women, breast-feeding, or women of childbearing potential not using a approved form of birth control | | | | | DBP response at 12 wk (seated trough DBP < 90 mm Hg and/or a ≥ 10 mm Hg reduction from baseline): Telmisartan: 59% Enalapril: 50% p < 0.05 Also reported 18–24 hr and 24 hr ABPM, daytime, and nighttime BP 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 76/265 (28.7%) Enalapril: 82/257 (31.9%) AE considered to be drug-related: Telmisartan: 20 (7.5%)D Enalapril: 34 (13.2%) 6 serious AEs (treatment group NR), none considered to be drug-related Discontinuation due to AEs: Telmisartan: 4 (1.5%) Enalapril: 8 (3.1%) 6) Specific adverse events:
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | | Telmisartan (n = 265) | Enalapril (n = 257)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | HA | 22 (8.3%) | 18 (7.0%)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | Cough | 2 (0.8) | 23 (8.9)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | Musculoskel pain | 12 (4.5) | 8 (3.1)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | Malaise/fatigue | 6 (2.3) | 9 (3.5)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | Hypotension | 3 (1.1) | 10 (3.9)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | Viral ENT infect | 8 (3) | 7 (2.7)
Amerena, Pappas, Ouellet, et al., 2002 #3620 | | | | | | | 7) Persistence/adherence: Compliance assessed by pill count at clinic visit; similar in both groups 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Avanza, El Aouar, and Mill, 2000 #5600 | Geographical location: Vitoria, Brazil Study dates: Unknown Funding source: Merck Sharp & Dhome – supplied meds Interventions: - [underlined: Enalapril] 20 mg qam + 15 mg qpm (n = 22) - Losartan 100 mg qam + 75 mg qpm (n = 17) - Enalapril 15 mg qam + losartan 100 mg qpm (n = 23) No dose titration; no co-interventions permitted Study design: Non-randomized controlled clinical trial (CCT) Groups assigned sequentially as patients were recruited: Enalapril → enalapril/losartan D→ losartan Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes (echocardiographers were blinded) Was allocation concealment adequate?: No Baseline/run-in period: 12-day washout of prior meds Duration of treatment: 10 months Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 90 - Eligible for inclusion: 61 - Allocated: 61 - Began treatment: 61 - Completed treatment: 46 - Withdrawals/losses to followup: 15 (4 due to cough, 4 stopped taking study med, 2 noncompliant, 2 altered medication schedule, 2 treatment failures, 1 acute MI) Age: Mean (SD): 54 ± 4 Sex (n [%]): Female: 19 (41%) Male: 27 (59%) Race/ethnicity (n [%]): “All were white or mulatto” (no numbers given) Baseline blood pressure: Office BP measured using a mercury sphygmomanometer after a 10-min rest in a seated position: Mean baseline values for n = 46 study completers: | | | | | 1) Blood pressure: Mean office SBP values reported in text for 7 mo. Posttreatment office DBP for all timepoints and office SBP for all other timepoints reported only graphically in Figure 1. Mean office SBP at 7 mo: Enalapril (n = 15): 146 ± 1.9 Losartan (n = 15): 146 ± 2.1 Enalapril + losartan (n = 16): 143 ± 1.9 p > 0.05 for between-group comparison of reductions from baseline At 10 mo, SBP values significantly (p < 0.05) higher in the losartan group than in the other 2 groups (shown only graphically in Figure 1) At the end of month 10 “almost all the patients” had BPs in the normal range (SBP < 140 mm Hg, DBP < 90 mm Hg) 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensives permitted) 3) Mortality: NR 4) Morbidity: 1 patient in the enalapril group had an acute MI 5) Safety: 4/22 patients (18%) in the enalapril group withdrew due to cough 6) Specific adverse events: NR 7) Persistence/adherence: 2/61 patients were noncompliant (both enalapril) 4/61 stopped taking study medication (2 losartan, 2 combination group) 2/61 altered medication schedule (both combination group) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Plasma glucose levels (mg%) were in the normal range for all patients and did not change significantly during treatment. There were no significant between-group differences | | | | | General comments: None Quality assessment: Overall rating: PoorD Comments: - Poor study design - Non-randomized, non-blinded - Small sample size - Non-responders and non-compliant patients excluded from analysis - Reported levels of SBP reduction are far greater than that typically reported in most studies - Missing data, including BP values at 10 months Applicability: - Minimal patient characteristics reported - Black patients excluded - Analyzed very selected population who completed study, complied with treatment, and responded to treatment (not ITT)
Avanza, El Aouar, and Mill, 2000 #5600 | | | [underlined: SBP] | [underlined: DBP] | | | | [underlined: Baseline] | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #5600 | | Enalapril | 173 ± 2.9 | 104 ± 1.8 | | | Enalapril (n = 15) | 90 ± 4 | 90 ± 4
Avanza, El Aouar, and Mill, 2000 #5600 | | Losartan | 170 ± 1.9 | 103 ± 1.7 | | | Losartan (n = 15) | 93 ± 4 | 94 ± 4
Avanza, El Aouar, and Mill, 2000 #5600 | | Enalapril + losartan | 173 ± 2.8 | 104 ± 1.5 | | | Enalapril + losartan (n = 16) | 91 ± 4 | 91 ± 4
Avanza, El Aouar, and Mill, 2000 #5600 | | 24-hr ABPM also performed using a SpaceLabs 90207 device, with readings every 20 min Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: University clinics Inclusion criteria: - Both sexes - Age 40–60 - Resting BP indicating moderate hypertension (by JNC-5) after run-in - Ambulatory BP confirming moderate hypertension - Echo criteria for LVH Exclusion criteria: - Black race - Obesity (BMI >30) - Diabetes - Valvular heart disease - Secondary hypertension - History of complications of hypertension (MI or CHF) - Long-term use of corticosteroids, neuroleptics or antidepressants | | | | | 11) LV mass/function: Mean LVMI (g/m^2^)
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | | [underlined: Baseline] | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Enalapril (n = 15) | 141 ± 3.9 | 123 ± 3.6
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Losartan (n = 15) | 147 ± 3.8 | 133 ± 2.8
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Enalapril +losartan (n = 16) | 146 ± 3.0 | 116 ± 4.0*
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | *p = 0.011, combination vs. enalapril and vs. losartan at 10 mo; p-values for all other between-group comparisons NS Percent reduction in LVMI from baseline to 10 mo (see Figure 3): Enalapril: 12.4 ± 3.2%* Losartan: 9.1 + 2.1% Enalapril + losartan: 20.5 ± 5.0%** *p < 0.05, enalapril vs. losartan **p < 0.01, combination vs. single treatments 12) Creatinine/GFR: Creatinine levels (mg%) were in the normal range for all patients and did not change significantly during treatment. There were no significant between-group differences.
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | | [underlined: Baseline] | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Enalapril (n = 15) | 1.2 ± 0.2 | 1.2 ± 0.3
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Losartan (n = 15) | 1.1 ± 0.3 | 1.2 ± 0.3
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | Enalapril + losartan (n = 16) | 1.2 ± 0.3 | 1.3 ± 0.3
Avanza, El Aouar, and Mill, 2000 #5600 | | | | | | | 13) Proteinuria: NR
Barnett, Bain, Bouter, et al., 2004 #11010 | Geographical location: 39 centers in northern Europe (Denmark, Finland, The Netherlands, Norway, Sweden, and the UK) Study dates: NR Funding source: Boehringer Ingelheim Interventions: - Telmisartan 40 mg daily for 4 weeks, then forced titration to 80 mg daily (n = 120) - Enalapril 10 mg daily for 4 weeks, then forced titration to 20 mg daily (n = 130) Additional antihypertensives (not ACEIs or ARBs) allowed after 2 mo if SBP > 160 or DBP > 100 Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: Yes Baseline/run-in period: 1 month – received regular antihypertensive meds including an ACEI (which was then stopped at randomization) Duration of treatment: 5 years Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 250 - Began treatment: 250 - Completed treatment: 168 - Withdrawals/losses to followup: 38 telmisartan group (20 due to AEs, 18 for other causes), 44 enalapril group (30 due to AEs, 14 for other causes) Age: Mean (SD): 60.6 (8.8) Median: NR Range: NR Sex (n [%]): Female: 68 (27%) Male: 182 (73%) Race/ethnicity (n [%]): White: 246 (98.4%) Other: 4 (1.6%) Baseline blood pressure: Measured at trough; method of assessment not further described Mean baseline values: | | | | | 1) Blood pressure: Adjusted mean reduction in SBP over 5 yr (last observation carried forward): | | | | | General comments: - Primary outcome of study was change in GFR Quality assessment: Overall rating: Fair Comments: - Many dropouts; GFR data based on data available in only 216 subjects (103 telmisartan, 113 enalapril) Applicability: - Patients all with diabetic nephropathy (~80% microalbuminuria, ~20% macroalbuminuria) - Minimal focus on HTN, details of BP assessment not described, and overall targets quite high compared to current recommendations
Barnett, Bain, Bouter, et al., 2004 #11010 | | | [underlined: Telmisartan] | [underlined: Enalapril] | | | | [underlined: Telmisartan] | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #11010 | | SBP | 152.6 ± 16.6 | 151.6 ± 15.8 | | | | 6.9 mm Hg | 2.9 mm Hg
Barnett, Bain, Bouter, et al., 2004 #11010 | | DBP | 85.4 ± 8.8 | 85.9 ± 7.8 | | | | 95% CI: | −8.5 to 0.5 mm Hg
Barnett, Bain, Bouter, et al., 2004 #11010 | | Concurrent medications (n [%]): Diuretics: 130 (52%) Beta-blockers: 98 (39.2%) Calcium channel blockers: 115 (46%) Other antihypertensive agents: 88 (35.2%) Aspirin: 98 (39.2%) Statins: 105 (42%) Comorbidities (n [%]): Duration of diabetes (median [range]): Telmisartan: 8.0 yr (0–25) Enalapril: 8.0 yr (0–37) History of cardiovascular disease: Telmisartan: 59 (49.2%) Enalapril: 63 (48.5%) Recruitment setting: Academic centers in northern Europe Inclusion criteria: - White or Asian race/ethnicity - Age 35–80 - Type 2 diabetes treated by diet, diet + oral hypoglycemic drugs (for ≥ 1 year), or insulin preceded by treatment with oral agents (for ≥ 1 year) - For patients treated with insulin, onset of diabetes > age 40 and BMI > 25 at time of diagnosis - History of mild-to-moderate hypertension (mean seated SBP ≤ 180 mm Hg) - Current resting BP < 180/95 mm Hg after ≥ 3 months of treatment with ACEI prior to study entry - Normal gross renal morphology for ≥ 12 months - Urinary albumin excretion rate (mean of 3 consecutive overnight values) of 11–999 μg/min, with 2 values > 10 μg/min - HbA1c < 12% - Serum creatinine ≤ 1.6 mg/dL (140 μmol/L) - GFR ≥ 70 mL/min/1.73 m^2^ - Women who were < 60 had to be either surgically sterile or have negative pregnancy test at enrollment Exclusion criteria [note – some of these are from a separate article describing methods]: - Renal dysfunction not due to diabetic nephropathy - Single kidney or known renal artery stenosis - New York Heart Association functional class II–IV CHF - Known allergy to study drugs or iohexol - History of angioedema related to ACEIs | | | | | Figure 2 demonstrates changes graphically. % of patients with: SBP < 160: 75% SBP < 140: 42% No significant difference between groups. 2) Rate of use of a single antihypertensive agent for BP control: Table 2 gives some information, but is imprecise. Based on figures reported, percentages of patients on monotherapy for hypertension during the study were in the following ranges: Telmisartan: 15–65% Enalapril: 18.5–64.6% 3) Mortality: Deaths: Telmisartan: 6 (3 due to CV events [stroke, MI, or cardiac insufficiency]) Enalapril: 6 (2 due to stroke) 4) Morbidity:
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | [underlined: Telmisartan] | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | Stroke | 6 | 6
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | CHF | 9 | 7
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | Non-fatal MI | 9 | 6
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | Incr Cr < 2.3 | 2 | 2
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | 5) Safety:
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | [underlined: Telmisartan] | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | Any AE: | 115 (95.8%) | 130 (100%)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | AE leading to study discontinuation:
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | 20 (17%) | 30 (23%)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | 6) Specific adverse events: See 4) above. Note that patients with know history of angioedema related to ACEIs were excluded. 7) Persistence/adherence: NR 8) Lipid levels: Pre-study levels recorded, post-study not given although stated “there were no changes in routine hematologic or blood chemical values in either group.” 9) Progression to type 2 diabetes: NA (all had type 2 diabetes with micro/macroalbuminuria) 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: See Fig 1 & Table 3 for details. Mean change from baseline (last observation carried forward):
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | Telmisartan (n = 103) | Enalapril (n = 113) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | GFR | −17.5 | −15.0 | −2.6 (−7.1, 2.0)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | Telmisartan (n = 116) | Enalapril (n = 128) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | Creat | 0.10 | 0.10 | 0 (−0.66, 0.65)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | 13) Proteinuria: Mean change from baseline (last observation carried forward):
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | | Telmisartan (n = 115) | Enalapril (n = 125) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | UAE* | 1.03 | 0.99 | 1.04 (0.71, 1.51)
Barnett, Bain, Bouter, et al., 2004 #11010 | | | | | | | *UAE = urinary albumin excretion (ratio)
Black, Graff, Shute, et al., 1997 #6850 | Geographical location: NR, but likely U.S. in Illinois, Florida, Texas, or Oregon Study dates: NR Funding source: NR, but one author each affiliated with GFI Pharmaceutical Services and Ciba-Geigy Corporation Interventions: - Valsartan 80 mg with titration to 160 mg once daily (n = 177) - Valsartan 80 mg with titration to 80 mg twice daily (n = 187) - Lisinopril 10 mg with titration to 20 mg once daily (n = 187 ) - Placebo (n = 183) Dose titration and co-interventions: Titration allowed after 4 wk for patients with mean seated DBP ≥ 90 and no symptoms of orthostatic hypotension; no co-interventions allowed Study design: RCT, parallel-group Stratified by age Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 734 - Began treatment: 734 - Completed treatment: 644 - Withdrawals/losses to followup: 90 (“most” due to AEs or unsatisfactory therapeutic response) Age: Mean (SD): 53.5 Median: NR Range: NR Sex (n [%]): Female: 39% Male: 61% Race/ethnicity (n [%]): White: 81% Black: 14% Other: 4% Baseline blood pressure: Trough seated BP measured 3 times each visit after 5-min rest using mercury sphygmomanometer Mean baseline values (± SD): | | | | | 1) Blood pressure: Mean post-treatment BP values NR Primary outcome = least mean square change in DBP from baseline (all randomized patients, using last available posttreatment BP measurement): Valsartan 80/160: -8.29 mm Hg Valsartan 80/80x2: −8.67 Lisinopril 10/20: −9.97 p = NS Results for change in SBP reported to be comparable (quantitative data NR) Per-protocol results for 12 wk also reported, but only graphically (Figure 2) BP response rates (mean DBP < 90 or ≥ 10 decrease from baseline; all randomized patients, using last available posttreatment BP measurement): Valsartan 80/160: 44.1% Valsartan 80/80x2: 48.7% Lisinopril: 10/20: 57.2% p = 0.012 for valsartan 80/160 vs. lisinopril p = NS for valsartan 80/80x2 vs. lisinopril 2) Rate of use of a single antihypertensive agent for BP control: No additional antihypertensives allowed 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Valsartan (any dose): 62.6% Lisinopril (either dose): 58.3% AEs considered to be drug-related: Valsartan: 22.8% Lisinopril: 27.8% Serious AEs and/or withdrawals due to AEs: Valsartan: 14/364 (3.8%) Lisinopril: 8/187 (4.3%) Drug-related AEs leading to withdrawal: Valsartan: 7 (headache 3, lightheadedness 1, shortness of breath 1, rash 1, fatigue 1) Lisinopril: 6 (cough 3, chest pain 1, nausea/dizziness 1, fatigue 1) 6) Specific adverse events: | | | | | General comments: Population not well specified, randomization not specified Quality assessment: Overall rating: Fair Comments: - Population not well specified - Method of randomization not described - Potential confounders/comorbidities not discussed - Some important outcomes not assessed; did not report unadjusted posttreatment DBP and SBP values Applicability: - Setting not specified, study centers not reported - Unclear how patients recruited - Exclusion criteria vague on what “clinically significant” means
Black, Graff, Shute, et al., 1997 #6850 | | | [underlined: SBP] | [underlined: DBP] | | | | Valsartan (n = 364) | Lisinopril (n = 187)
Black, Graff, Shute, et al., 1997 #6850 | | Valsartan | 153.64 | 100.81 | | | Headache | 7.7% | 3.2%
Black, Graff, Shute, et al., 1997 #6850 | | 80/160 | ± 11.07 | ± 4.41 | | | Viral infection | 0.3% | 0%
Black, Graff, Shute, et al., 1997 #6850 | | Valsartan | 154.27 | 101.66 | | | URI | 0.5% | 0%
Black, Graff, Shute, et al., 1997 #6850 | | 80/80x2 | ± 14.95 | ± 4.83 | | | Fatigue | 2.2% | 3.7%
Black, Graff, Shute, et al., 1997 #6850 | | Lisinopril | 153.93 | 100.99 | | | Back pain | 0.3% | 0%
Black, Graff, Shute, et al., 1997 #6850 | | 10/20 | ± 14.94 | ± 4.45 | | | Diarrhea | 1.6% | 2.1%
Black, Graff, Shute, et al., 1997 #6850 | | Concurrent medications (n [%]): NR, but no BP lowering meds allowed Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age 21–80 yr - Stage I–III diastolic HTN (seated DBP ≥ 95 and ≤ 115 after placebo run-in period) Exclusion criteria: - Symptomatic CHF, MI, hypertensive encephalopathy, or CV accident < 6 mo - 2^nd^ or 3^rd^ degree heart block - Angina - Clinically relevant arrhythmias - Clinically significant valvular disease - Significant hepatic disease - Significant renal disease - Insulin-dependent diabetes - Women of childbearing age not using contraception | | | | | Cough | 1.1% | 8.0%
Black, Graff, Shute, et al., 1997 #6850 | | | | | | | Dizzy | 1.1% | 3.7%
Black, Graff, Shute, et al., 1997 #6850 | | | | | | | Sinusitis | 0.3% | 1.1%
Black, Graff, Shute, et al., 1997 #6850 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | Geographical location: Throughout US Study dates: Jul 1995 to Jun 1996; subsequent study reported followup to Jun 2000 Funding source: Merck & Co., Inc. Interventions: ARB (n = 567) ACE inhibitor (n = 5842) CCB (n = 5094) Beta-blocker (n = 4994) Thiazide diuretic (n = 5226) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 4 yr | Number of patients: - Screened for inclusion: 1.3 to 1.6 million - Eligible for inclusion: NA - Randomized: NA - Began treatment: 21,723 - Completed treatment: NA - Withdrawals/losses to followup: 6548 lost by 4-year followup Age: Mean (SD): 56 (NR) Median: NR Range: 35–71 Sex (n [%]): Female: 12,148 (55.9%) Male: 9575 (44.1%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): 0 [0%] (not allowed) Comorbidities (n [%]): NR (attempted to eliminate subjects with comorbid conditions based on concurrent prescriptions) Recruitment setting: Enrollees in pharmacy benefit management program which includes HMO, Blue Cross-Blue Shield, and union, corporate, and government clients Inclusion criteria: - Patients filling first antihypertensive drug prescription in one of 5 classes (ARB, ACEI, CCB, beta-blocker, thiazide) during study period - No prescription filled for any antihypertensive drug in prior 12 mo Exclusion criteria: - Prescription for nitrate, antiarrhythmic, digoxin, warfarin, loop diuretic, or certain anti-migraine drugs - Concurrent prescriptions for two or more antihypertensive drug classes (including combination products) - Incomplete data on age and sex | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Based on prescription refill on or within 3 mo after 1-yr anniversary of initial prescription 1-year data: | | | | | General comments: - The large sample size and representative population of the PBM database are strengths of the study, but rating is downgraded because of lack of specificity regarding hypertensive diagnosis and comorbidity, as well as no dose info; correlation between dose and BP response and change in prescription - Reasons for discontinuing therapy are not captured (ineffective? adverse events?) - ARBs were introduced just 1 year before the study period, suggesting that prescribing patterns may have been in flux – may not be representative of current patterns Quality assessment: Overall rating: Fair Comments: - Appears to be well done study for administrative database Applicability: - Lack of clinical data on subjects means that baseline BP data, BP response, actual comorbidities are unknown
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Drug | Continued | Switched | D/c’d
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | ARB | 64% | 7% | 29%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | ACEI | 58% | 9% | 33%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | CCB | 50% | 9% | 41%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Beta-B | 43% | 7% | 50%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Thiaz | 38% | 6% | 56%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | In multivariable analysis: - Age ≥ 65 years was associated with higher persistence than age between 40 and 64 years (OR, 0.79; 95% CI, 0.74 to 0.84; p = 0.001) and age < 40 years (OR, 0.32; 95% CI, 0.29 to 0.35; p = 0.0001) - Dosing more than once daily was associated with lower persistence than once-daily dosing (OR, 1.40; 95% CI, 1.29 to 1.52; p = 0.0001) 4-year data:
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Drug | Continued | Switched | D/c’d
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | ARB | 50.8% | 16.5% | 32.7%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | ACEI | 46.5% | 18.9% | 34.6%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | CCB | 40.7% | 19.3% | 40.0%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Beta-B | 34.7% | 12.7% | 52.6%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | Thiaz | 16.4% | 32.6% | 51.0%
Bloom, 1998 #12630 and Conlin, Gerth, Fox, et al., 2001 #12640 | | | | | | | - Persistence with ARB (92% losartan) was higher than persistence with CCBs, beta-blockers or thiazides (p < 0.03), but not higher than ACEI (p = 0.095). - Persistence was higher among women than men, and higher among patients ≥ 65 years of age than those < 65 years of age 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Bourgault, Senecal, Brisson, et al., 2005 #12820 | Geographical location: Saskatchewan, Canada (database including > 90% of provincial residents) Study dates: Jan 1994-Sep 1999 Funding source: Merck Frosst Canada, Ltd. Interventions: Number of patients with data for at least 180 days: ARBs (n = 1002) ACEIs (n = 7104) Beta-blockers (n = 3989) CCBs (n = 2400) Diuretics (n = 6831) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Mean length of followup in ARB and ACEI groups = 1.85 yr | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 21,326 - Randomized: NA - Began treatment: NA - Completed treatment: NA - Withdrawals/losses to followup: NA Age (ARBs and ACEIs): Mean: 57.6 Median: NR Range: NR Sex (ARBs and ACEIs; %): Female: 45.7% Male: 54.3% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Populationbased prescription drug database Inclusion criteria: - ICD-9 code diagnosis of hypertension (401, 402, 403, 404, or 4-digit codes included in these categories) - Age 18–80 yr - New dispensed antihypertensive med between Jan 1997 and Sep 1999 - Antihypertensive prescribed was ARB, ACEI, beta-blocker, CCB, or diuretic Exclusion criteria: - Prescribed more than one antihypertensive agent at treatment initiation | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Sample sizes at various timepoints: | | | | | General comments: - Cohort studied overlaps with that studied in Marentette, Gerth, Billings, et al., 2002 (#12830); includes fewer total patients, but many more taking ARBs Quality assessment: Overall rating: Fair Comments: - Non-random allocation to drugs - No data on comparability of patients on ACEIs versus ARBs - Funded by pharmaceutical company Applicability: - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | | [underlined: ARBs] | [underlined: ACEIs]
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 1 year | 463 | 3456
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 2 years | 148 | 1541
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 3 years | 5 | 265
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | Persistence defined as continuously refilling a prescription for any antihypertensive drug within 90 days of previous dispensing (assumed to last 15–30 days), regardless of switches across drug classes and add-on therapies. Cumulative persistence:
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | | [underlined: ARBs] | [underlined: ACEIs]
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 1 year | 66% | 59%
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 2 years | 56% | 47%
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | 3 years | 53% | 40%
Bourgault, Senecal, Brisson, et al., 2005 #12820 | | | | | | | Similar results were observed after controlling for age and sex, which were not explicitly noted as being statistically significant. Note: “Persistence” includes combinations and switches; in essence, what is being modeled is failure to discontinue. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Burke, Sturkenboom, Lu, et al., 2006 #12880 | Geographical location: 694 general practices widely distributed across the UK (less coverage in Scotland and inner London) Study dates: Jan 1991 – Mar 2002 Funding source: Merck & Co., Inc. Interventions: Numbers reported below are the % of patients given a drug from the specified class as their first prescription and the total number of “drug class episodes,” respectively ACEI (12.2%; 36,386) ARB (0.5%; 5184) α-antagonist (1.1%; 7823) Beta-blocker (27.4%; 54,973) CCB (12.5%; 41,019) Potassium-sparing diuretic (0.2%; 1831) Thiazide (42.0%; 71,331) Miscellaneous monotherapy (0.3%; 4681) Combination (3.7%; NA) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 4 yr | Number of patients: - Screened for inclusion: > 9 million - Eligible for inclusion: 109,454 - Randomized: NA - Began treatment: 109,454 - Completed treatment: NA - Withdrawals/losses to followup: NA Age: Mean (SD): 60.6 (13.4) Median: NR Range: | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Discontinuation was analyzed based on a Kaplan-Meier analysis of time until 90+ dayspassed without a refill. Investigators also performed a Cox regression using the same outcome variable and controlling for various patient factors (age, number of previous antihypertensive drug classes, calendar year of antihypertensive therapy initiation, pretreatment SBP, duration of hypertension, smoking). The results of this modeling are substantially similar to the unadjusted analysis presented immediately below. Cumulative discontinuation rates: | | | | | General comments: - Outcomes of interest were analyzed on the basis of the number of drugclass episodes (223,228), not number of patients (109,454) Quality assessment: Overall rating: Poor Comments: - Non-random allocation to drugs - Time period of study includes considerable period before ARBs were available; allocation of patients to ACEIs versus ARBs may as a result be biased - No measurement, reporting, or adjustment for potential confounders - No data on comparability of patients on ACEIs versus ARBs Applicability: - UK location and different health system may affect use rates/patient characteristics - Study period soon after introduction of ARBs; early use may not reflect current use patterns - Specific ACEIs and ARBs not identified - Diabetics excluded
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | < 50 | 22.4% | | | | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr]
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | 50–59 | 25.1% | | | ACEIs | 37.8% | 48.0% | 54.8% | 60.4%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | 60–69 | 25.5% | | | ARBs | 29.4% | 41.3% | 50.3% | 57.8%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | ≥ 70 | 27.0% | | | α-antag | 44.7% | 56.5% | 64.4% | 69.9%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | Sex (n [%]): Female: 56.5% Male: 43.5% Race/ethnicity (n [%]): NR Baseline blood pressure: Mean SBP (± SD): 173.5 ± 21.1 Mean DBP (± SD): 99.7 ± 27.3 Concurrent medications (n [%]): NR; patients with pre-existing diabetes prescription excluded Comorbidities (n [%]): NR; patients with pre-existing diabetes diagnosis excluded Recruitment setting: UK General Practice Research Database. Contains information (demographic descriptors, information from GP visits, GP prescription data [used to generate written prescriptions], diagnoses from specialist referrals and hospital admissions, and lab results) on > 9 million patients. Inclusion criteria: - Age ≥ 18 - New physician diagnosis of hypertension between 1 Jan and 31 Dec 2001 (“new” diagnosis = no hypertension diagnoses prior to 1 Jan 1991 and no antihypertensive prescription within 1 year of new diagnosis) Exclusion criteria: - Diabetes diagnosis or diabetes prescription before antihypertensive prescription | | | | | BB | 44.0% | 54.3% | 61.2% | 66.7%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | CCB | 41.2% | 51.5% | 58.8% | 64.7%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | K-diuretic | 64.1% | 74.9% | 81.1% | 84.9%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Thiazide | 43.9% | 55.4% | 63.1% | 69.3%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Misc | 62.8% | 75.0% | 81.1% | 84.8%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Switching was defined only for the subset of patients that discontinued their first line antihypertensive:
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | ACEIs | 44.2%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | ARBs | 36.5%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | α-antag | 38.2%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | BB | 44.8%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | CCB | 43.4%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | K-diuretic | 30.4%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Thiazide | 44.6%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Misc | 25.9%
Burke, Sturkenboom, Lu, et al., 2006 #12880 | | | | | | | Even though the investigators’ modeling controlled for various patient characteristics, it was not possible to determine which of these characteristics were predictive of persistence. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | Geographical location: NR (author based in Turkey) Study dates: NR Funding source: NR Interventions: - Ramipril 10 mg (n = 50) - Telmisartan 80 mg telmisartan (n = 50) Study design: RCT, parallel-group Blinding: - Patients: NR - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: NR Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 100 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean (SD): 51.79 ±6.01 Median: NR Range: NR Sex (n [%]): Female: 44 (44%) Male: 56 (56%) Race/ethnicity (n [%]): NR Baseline blood pressure: BP measured 3 times after a 10-min resting period using a standard mercury sphygmanometer; mean of 3 measurements used | | | | | 1) Blood pressure: At 6 months, n = 50 each group: | | | | | General comments: None Quality assessment: Overall rating: Poor Comments: - Significant missing data – timing, funding of study, the number screened, the number that completed treatment - Study and assessment were not blinded; may lead to bias - No data on safety/adverse events Applicability: - Many common conditions excluded - No information on number screened or recruitment setting - No data on race/ethnicity of subjects
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | | [underlined: Telmisartan] | [underlined: Ramipril] | | | | [underlined: Telmisartan] | [underlined: Ramipril] | [underlined: p-value]
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | SBP | 155.9 ± 6.75 | 154.3 ± 5.44 | | | SBP | 133.5 ± 9.48 | 130.4 ± 13.39 | 0.18
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | DBP | 96.4 ± 6.47 | 94.7 ± 5.83 | | | DBP | 81.4 ± 6.06 | 80.2 ± 7.75 | 0.39
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): DM: 17 (17%) Family history of premature CAD: 19 19%) Smoking: 26 (26%) Recruitment setting: NR Inclusion criteria: 100 newly diagnosed hypertensive patients without the below exclusions Exclusion criteria: - Secondary or malignant hypertension - Chronic obstructive lung disease - Atrial fibrillation, flutter, or any other atrial tachyarrhythmia’s with 1 month - History of anti-arrythmic drugs, including digoxin, within 1 month - Hyperthyroidism - Severe valvular disease of hemodynamic significance - History of sensitivity to use of ACEIs or ARBs - Pregnancy or nursing - MI or cerebrovascular accident within 6 months - History of proven coronary artery disease - Concurrent therapy with medication that could affect blood pressure - Severe renal or hepatic failure | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: Atrial fibrillations occurred in 4 patients in enalapril arm and 2 patients telmisartan arm 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LVEF
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | | | | | | | [underlined: Telmisartan] | [underlined: Ramipril]
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | | | | | | Before | 61.58 ± 2.06 | 61.96 ± 1.87
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | | | | | | After | 61.70 ± 1.54 | 61.94 ± 1.40
Celik, Iyisoy, Kursaklioglu, et al., 2005 #890 | | | | | | | 12) Creatinine/GFR: NR 13) Proteinuria: NR
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | Geographical location: Multicenter trial: 17 centers in Spain Study dates: NR Funding source: Sanofi-Synthelabo Spain Interventions: Doses (titrated doses if DBP ≥ 90 after 4 or 8 weeks of treatment): - Irbesartan 150 mg/d (300 mg); n = 111, dose titration in 80 (72%) - Enalapril 10 mg/d (20 mg); n =115, dose titration in 88 (76.5%) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 3-wk single-blind placebo phase; patients with mean daytime DBP < 85 mm Hg during this period were excluded Duration of treatment: 12 weeks Duration of post-treatment followup: 24 hours after last dose of study medication | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 295 - Randomized: 238 - Began treatment: 238 - Completed treatment: 226 - Withdrawals/losses to followup: 12 (5 due to AEs, 4 lost to followup, 3 due to lack of efficacy) Age: Mean (SD): 52.7 ± 10.6 yr Median: NR Range: 22–73 Sex (n [%]): Female: 52% Male: 48% Race/ethnicity (n [%]): 100% white Baseline blood pressure: Clinic BP using mercury sphygmomanometer: After resting for 10 minutes in seated position; nondominant arm supported and cuff arm at heart level. 3 successive readings at 3 min intervals, mean of 3 values recorded. | | | | | 1) Blood pressure: Posttreatment seated trough BP values not reported ABPM results: 24-hr BP at 12 wk: | | | | | General comments: - Baseline 24-hour SBP significantly higher in irbesartan group (mean 4 mm p = 0.003) Quality assessment: Overall rating: Fair Comments: - Very little baseline information - Randomization process not described - Patients who failed treatment (BP ≥ 180/110 despite full-dose treatment) excluded (n = 3) Applicability: - All white patients - Recruitment setting not clearly described - Process of inclusion of study centers not described - Comorbid conditions not described: they were “excluded” but list of criteria not mentioned
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | [underlined: Irbesartan] | [underlined: Enalapril] | | | | Irbesartan (n = 111) | Enalapril (n = 115)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | SBP | 160.3 ± 14.1 | 158.2 ± 13.8 | | | SBP | 128.8 ± 13.8 | 127.2 ± 11.1
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | DBP | 101.6 ± 4.7 | 102.0 ± 5.2 | | | DBP | 79.9 ± 8.8 | 80.5 ± 8.1
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | 24-hr ABPM using a non-invasive automated oscillometric device (Spacelabs 90207); cuff placed on non-dominant arm, BP recorded at 20-min intervals automatically for 24 hr | | | | | Baseline and 12-wk mean BPs also reported for ambulatory daytime BP (= average 10 a.m. to 8 p.m.) and nighttime BP (average 12 – 6 a.m.) Mean reductions in 24-hr ABPM BP:
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | Irbesartan (n = 115) | Enalapril (n = 123) | | | | Irbesartan(n = 111) | Enalapril(n = 115)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | SBP | 144.2 ± 11.5 | 140.1 ± 11.9 | | | SBP | 14.7 ± 14.7 | 12.6 ± 13.1
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | DBP | 89.9 ± 6.3 | 89.6 ± 7.9 | | | DBP | 9.4 ± 8.5 | 8.8 ± 8.5
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | Concurrent medications (n [%]): No other antihypertensives or any other drugs with effects on the cardiovascular system permitted Comorbidities (n [%]): NR; patients with severe concomitant disease excluded Recruitment setting: NR Inclusion criteria: Mild-moderate hypertension (clinic DBP 90–109 mm Hg on ≥ 3 occasions, SBP 140–179 mm Hg or uncontrolled hypertension (BP ≥ 140/90) despite monotherapy with antihypertensive drugs other than ACE inhibitors or ARBs Exclusion criteria: - Renal impairment (Ser Cr > 1.5 mg/dL), papilledema, or evidence of coronary heart disease or cardiac failure during the previous 3 months - Severe concomitant disease - Women who were pregnant or of childbearing potential | | | | | Between-group p-value NS Mean reductions in seated trough BP:
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | | Irbesartan (n = 111) | Enalapril (n = 115)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | SBP | 19.0 ± 14.1 | 17.5 ± 14.0
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | DBP | 12.7 ± 8.8 | 12.4 ± 7.4
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Between-group p-value NS Seated trough BP – response rates: 36% (40/111) of patients treated with irbesartan and 34.8% (40/115) of those treated with enalapril achieved strict BP control (clinic BP < 140/90 at 12 wk). Response rates based on the clinic criterion (DBP reduction of ≥ 10 mm Hg at 12 wk) were 64.0% (71/11) and 67.8% (78/115), respectively. 24-hr ABPM – response rates: 40.5% (45/111) of patients with irbesartan and 33.9% (39/115) with enalapril achieved strict BP control (daytime BP < 130/85 at 12 wk), with no significant difference between groups. Response rates (reduction in 24-hr DBP of ≥ 5 mm Hg at 12 wk independent of clinic values) were 71.2% (79/111) and 71.3% (82/115), respectively. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | | Irbesartan n (%) | Enalapril n (%)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Any AE | 46 (40) | 63 (51.2)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Discontinued due to AEs | 2 (1.7) | 3 (2.4)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | AEs deemed probably related to treatment were less frequent with irbesartan than with enalapril (9.2% vs. 24.6%, p = 0.026) Risk of AEs deemed probably related to treatment: 2.6 times higher in those treated with enalapril (OR 2.6, 95% CI 1.1 to 6.1) Discontinued due to AEs in irbesartan group (n = 2): GI disturbance, nausea, vomiting Discontinued due to AEs in enalapril group (n = 3): skin rash, persistent cough 6) Specific adverse events: Most common AEs (> 5% in either group):
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | | Irbesartan n (%) | Enalapril n (%)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Nervous system | 22 (19.1) | 33 (26.8)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Fatigue, back pain, fever | 16 (13.9) | 10 (8.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | GI system | 12 (10.4) | 8 (6.5)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Headache | 11 (9.6) | 18 (14.6)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Dizziness | 9 (7.8) | 17 (13.8)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Cardiovascular system | 8 (7.0) | 9 (7.3)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Palpitations | 7 (6.1) | 8 (6.5)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Upper resptract | 4 (3.5) | 18 (14.6)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Cough | 1 (0.9) | 10 (8.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | Skin disorders | - | 5 (4.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #4500 | | | | | | | 7) Persistence/adherence: Compliance with treatment (assessed by pill counts at each visit) similar in two groups: 98.3% in patients treated with irbesartan and 98.4% in those treated with enalapril Irbesartan once daily better tolerated than enalapril once daily 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | Geographical location: 36 sites in Italy, France, Germany Study dates: NR Funding source: Takeda Italia Interventions: - Candesartan 8–16 mg qd (n = 115) - Enalapril 10–20 mg qd (n = 124) Dose titration/co-interventions: - Higher dose of study drug used after 4 wk if BP not controlled (≥ 140/90 mmHg or DBP reduced < 10 mmHg and SBP < 20%) -After 4 additional wk, if BP not controlled, HCTZ 12.5 mg added and titrated up to 25 mg as needed Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes Baseline/run-in period: 2- to 4-week run-in with single-blind placebo, previous antihypertensive treatments withdrawn Duration of treatment: 48 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 304 - Eligible for inclusion: 239 - Randomized: 239 - Began treatment: 239 - Completed treatment: 182 - Withdrawals/losses to followup: 57 (19 due to AEs, 12 withdrew consent, 14 lack of efficacy, 12 “other”) - ITT population = 196 - Per-protocol population = 145 Age: Mean (SD): 52.9 Median: NR Range: NR Sex (n [%]): Female: 74/196 (38%) Male: 122/196 (62%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a mercury sphygmomanometer; 3 readings taken at 1-min intervals after patient seated for 5 min of rest. Mean of 3 readings used. | | | | | 1) Blood pressure: BP was measured at the end of placebo period and at 4, 8, 12, 24, 36, and 48 weeks Mean post-treatment BP values NR Mean changes in SBP and DBP from baseline to last available timepoint (ITT population): No significant difference between the two treatments (no quantitative data or statistical tests shown) Similar results (no significant between-group differences) for mean changes in SBP and DBP at 24 and 48 wk in the per-protocol population (no quantitative data or statistical tests shown) The percentage of patients achieving BP normalization (defined as < 140/90 mmHg): Candesartan: 60.4% Enalapril: 60.0% No statistical testing shown; not clear whether ITT or per-protocol population 2) Rate of use of a single antihypertensive agent for BP control: ITT analysis (n = 196 patients) Patients receiving study drug alone (with no HCTZ): Candesartan: 54.3% Enalapril: 45.8% Per-protocol analysis (n = 145 patients) Patients receiving study drug alone (with no HCTZ): Candesartan: 61.0% Enalapril: 53.4% 3) Mortality: NR 4) Morbidity: NR 5) Safety: There were no serious AEs Adverse events: | | | | | General comments: - Emphasis on a non-biased approach and interpretation of results Quality assessment: Overall rating: Fair Comments: - Would have been compelling if article included the mean BP measurements taken at 4, 8, 12, 24, 36, and 48 wk - May be error in randomization, as female low in the enalapril group (34% vs. 42% in candesartan group) Applicability: - No data on race/ethnicity of subjects - Restricted to patients with LVH
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | | Candesartan(n = 91) | Enalapril (n = 105) | | | | N (%) | Withdrawals (n)
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | SBP | 163.1 ± 9.7 | 162.4 ± 8.9 | | | Candesartan | 16 (14%) | 6
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | DBP | 101.5 ± 3.9 | 101.0 ± 4.4 | | | Enalapril | 24 (19%) | 13
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age 25–70 yr - Hypertension (SBP 150–200 mm Hg and DBP 95–115 mm Hg at end of placebo run-in period) - LVH (LVMI > 120g/m2 in men and LVMI > 100g/m2 in women) Exclusion criteria: - Adequate M-mode echo cardiogram not obtained - Clinical or echocardiographic evidence of significant valvular disease - Coronary heart disease - CHF - Dilated LV chamber (end diastolic diameter > 60 mm) | | | | | 6) Specific adverse events: Cough occurred in 9% of enalapril patients and in 3% of candesartan patients 7) Persistence/adherence: Compliance measured by counting return tablets; no results reported. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LV mass estimated by Devereux’s formula and normalized for body surface LVMI (g/m2) measurements by echocardiographic and Doppler (ITT population):
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | | | | | | | Baseline | Treatment (last available timepoint)
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | | | | | | Candesartan (n = 91) | 141.0 ± 24.1 | 126.0 ± 32.4
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | | | | | | Enalapril | 143.4 ± 27.5 | 130.1 ± 29.3
Cuspidi, Muiesan, Valagussa, et al., 2002 #3790 | | | | | | | (n = 105) The decrease in LV mass was accomplished by substantial reduction in interventricular septum and posterior wall thickness in both treatment groups. 12) Creatinine/GFR: NR 13) Proteinuria: NR
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | Geographical location: Naples, Italy Study dates: NR Funding source: NR Interventions: - Enalapril 5–20 mg (n = 24) - Losartan 12.5–50 mg (n = 26) Dose titration: - Enalapril started at 5 mg daily, titrated q 7 days, as tolerated, to 10 mg and 20 mg daily if DBP ≥ 90 - Losartan started at 12.5 mg daily, titrated q 7 days, as tolerated, to 25 mg and 50 mg daily if DBP ≥ 90 No co-interventions permitted Study design: RCT, parallel-group Blinding: - Patients: Yes (double-dummy) - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 3 years Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 50 - Began treatment: 50 - Completed treatment: 42 - Withdrawals/lost to followup: 8 (3 due to AEs, 2 lost to followup, 2 non-responders, 1 other) Age: For randomized group n = 50 - Mean (SD): 52 yrs (7.7) - Median: NR - Range: NR For analyzed group completing study n = 42 - Mean: 55 (SD not reported) - Range: 52–62 -<br Sex (n [%]): (#s given are for analyzed 42 pts) Female: 21 (50%) Male: 21 (50%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomanometer after 5 min rest; average of 3 readings taken at 1-min intervals | | | | | 1) Blood pressure: Seated trough mean difference in BP (95% CI) at 3 yrs: p value - NS Losartan (n = 22) Pre- 155/103 Post- 140/92 Mean diff SBP -14.5mmHg (−22.6, −6.4) Mean diff DBP −10.5mmHg (−13.5, −7.6) Enalapril (n = 20) Pre- 159/102 Post- 144/91 Mean diff SBP -14.6 (−27.4, −1.7) Mean diff DBP −11.4 (−14.8, −8.1) 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensive meds permitted) 3) Mortality: NR 4) Morbidity: No quantitative data reported. Number of patients assessed unclear for most measures. QOL: “battery-of-scales” QOL instrument at baseline and after 12 wk of therapy. There were no statistical differences between the two therapies in the domains of general health, sexual functioning, or for the other scales of quality of life. For symptom bother, there was no between- group difference in HA or flushing, but there was a significantly higher incidence of “bother due to cough” in the enalapril patients than in losartan patients after 3 years of treatment, regardless of whether the symptom was present at baseline (12% vs. 2%; p = 0.01). 5) Safety: Withdrawals due to AEs: Losartan: 0/26 Enalapril: 3/24 (12.5%) 6) Specific adverse events: In patients completing treatment (n = 42), frequency of cough was: - Losartan 2% - Enalapril 12% (p = 0.01) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LV mass index change pre-/post- (baseline to 3 yr) using 2-D echocardiogram (g/m^2^): | | | | | General comments: - 2/26 pts in losartan group withdrew due to ineffective therapy and were excluded from analysis; 0/24 were excluded from enalapril for this reason. This biases BP results in losartan’s favor. Quality assessment: Overall rating: Fair Comments: See comments above and below. Applicability: - Small number of patients from single center in Italy - Minimal information on patient characteristics - Analyzed according to treatment completion and excluded those in whom therapy was ineffective
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | [underlined: Losartan] | [underlined: Enalapril] | | | | Pre- | Post- | Change (95% CI)
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | SBP | 155 ± 17 | 159 ± 19 | | | Losartan: | 176 ± 24 | 124 | −52 (−110.5, 32)
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | DBP | 103 ± 4 | 102 ± 5 | | | Enalapril: | 170 ± 19 | 129 | −41(−90.3, 21.9)
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | Concurrent medications (n [%]): NR; no non-study antihypertensives permitted Comorbidities (n [%]):See Exclusion criteria (below); otherwise NR Recruitment setting: Outpatient clinic Inclusion criteria: - Essential HTN - WHO stage II (SBP >140 and/or DBP > 90) Exclusion criteria: - Sig cardiovascular, cerebrovascular, renal, or hepatic disease. - Recent MI - Secondary HTN - “Clinicially significant lab abnormalities” | | | | | P-value for between-group difference NR 12) Creatinine/GFR: GFR measured by renal scintigraphy at baseline and 3 yr (mL/min ± SD):
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | | | | | | Losartan | Enalapril
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | | | | | Baseline | 96.5 ± 32.3 | 94.8 ± 31.1
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | | | | | 3 yr | 108.6 ± 31.1 | 99.8 ± 19.6
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | | | | | P-value | < 0.005 | 0.085
De Rosa, Cardace, Rossi, et al., 2002 <br#4470 | | | | | | | 13) Proteinuria: NR
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | Geographical location: Ravenna, Italy (databases of a local health unit) Study dates: Jan-Dec 1997 Funding source: Local health unit and Merck Sharp & Dohme Italia S.p.A. Interventions: ACEIs (n = 4986) ARBs (n = 317) CCBs (n = 4680) Diuretics (n = 4341) Beta-blockers (n = 2459) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Data reported for 1 and 3 years | Number of patients: - Screened for inclusion: 19,124 - Eligible for inclusion: 16,783 - Randomized: NA - Began treatment: NA - Completed treatment: NA - Withdrawals/losses to followup: NA Age (ACEIs and ARBs): Mean: 56.1 Median: NR Range: 20–105 Sex (ACEIs and ARBs, %]): Female: 52.6% Male: 47.4% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Persistence described under heading of “continuing,” “switching,” and “discontinuing” therapy; arbitrary minimum of 273 days used as cutoff. Continuing defined as persisting with original drug therapy, even if combined with an agent from another class. Switching defined as persisting with drug treatment, but switching to a drug of a different class. Discontinuing defined as giving up drug therapy altogether. 1-year data: | | | | | General comments: - Small sample sizes for ARBs at 1 year (n = 317) and 3 years (n = 198) Quality assessment: Overall rating: Fair Comments: - Non-random allocation to drugs - No data on comparability of patients on ACEIs versus ARBs - Funded by pharmaceutical company Applicability: - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | | [underlined: ACEIs] | [underlined: ARBs] | | | | Continue | Switch | Discontinue
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | Cardiopathy | 1.3% | 0.9% | | | ACEIs | 30.7% | 9.4% | 59.9%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | Diabetes | 2.1% | 1.3% | | | ARBs | 33.4% | 24.6% | 42.0%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | Asthma/COPD | 1.2% | 1.3% | | | Persistence was related to older age, taking medication for heart disease or diabetes, history of previous hospitalizations for CV events, and presence of ≥ 2 comorbidities. 3-year results: No quantitative data reported. Persistence was related to older age, young general practitioner, male general practitioner, and male sex. ARBs had better persistence throughout the followup period, but precise estimates could not be derived from Figure 2. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | Previous hosp for CV disease | 7.9% | 8.2%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | ≥ 2 comorbidities | 1.6% | 3.2%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #12800 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #12810 (3-year results) | | Recruitment setting: Database of local health unit Inclusion criteria: - New user of antihypertensive drug (not prescribed any antihypertensive drugs during previous 12 mo) - Age ≥ 20 years - Received first prescription for a diuretic, beta-blocker, CCB, ARB, or ACEI during study period Exclusion criteria: - Prescriptions for ≥ 2 antihypertensive agents or for a combination agent involving ≥ 2 classes - History of ≥ 3 prescriptions for cardiovascular, antidiabetes, or antiasthmatic/COPD drugs over previous 12 mo
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions: - Perindopril 4 mg (n = 49) - Candesartan 16 mg (n = 47) Dose titration and co-interventions: No titration; no co-interventions allowed Study design: RCT, parallel-group Blinding: Patients: Yes - Providers: NR - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 mo Duration of post-treatment followup: Patients followed for an additional month at the end of the trial after discontinuation of study meds | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 96 - Began treatment: 96 - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean (SD): 54 median: NR Range: NR Sex (n [%]): Female: 49 (51%) Male: 47 (49%) Race/ethnicity (n [%]): NR, but presumably 100% Caucasian Baseline blood pressure: Trough seated BP measured 3 times at 1-min intervals after patient rested 10 min using a standard mercury sphygmomanometer (Erkameter 3000); average of 3 readings used | | | | | 1) Blood pressure: Mean change (± SD) in BP from baseline to 12 mo: | | | | | General comments: - Probably underpowered study Quality assessment: Overall rating: Good Applicability: - Very early diabetes with mild hypertension - Patients in academic medical center in Italy - Probably underpowered to detect true differences between the groups
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | [underlined: Perindopril] | [underlined: Candesartan] | | | | [underlined: Perindopril] | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | SBP | 147 ± 6 | 148 ± 6 | | | SBP | −13 ± 4.5 | −12 ± 4.1
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | DBP | 94 ± 4 | 93 ± 5 | | | DBP | −11 ± 3.6* | −8 ± 2.9
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | Concurrent medications (n [%]): Glibenclamide: 43%Glipizide: 30% Gliclazide: 28% Comorbidities (n [%]): NR Recruitment setting: Department of Internal Medicine and Therapeutics at a single university hospital Inclusion criteria: - Type 2 diabetes diagnosed < 6 mo before - Mild hypertension (DBP 90–105 without meds) - Non-smokers - Adequate glycemic control (HbA1c < 7.5%) with diet or oral hypoglycemic drugs - Not on hypocholesterolemic drugs - No retinopathy, neuropathy, or nephropathy Exclusion criteria: - Secondary hypertension - Malignant hypertension - Unstable angina - MI within 6 months - Liver disease - Renal disease - Contraindication to ACEI or ARB - Already receiving ACEI or ARB | | | | | * p < 0.05, perindopril vs. candesartan; no other between-group comparisons statistically significant 1-mo, 6-mo, 1-mo posttreatment followup data also reported 2) Rate of use of a single antihypertensive agent for BP control: NA (no additional agents allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Perindopril: 5/49 (10%) Candesartan: 3/47 (6%) No serious AEs. No withdrawals due to AEs. 6) Specific adverse events: Perindopril (n = 49): 2 (4%) cough, 4 (8%) abnormal taste, 1 (2%) epigastric discomfort Candesartan (n = 47): 1 (2%) headache, 2 (4%) dizziness, 1 (2%) nausea 7) Persistence/adherence: NR 8) Lipid levels: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | | [underlined: Perindopril] | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | LDL baseline | 120 ± 18 | 125 ± 15
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | LDL change | −14 ± 7.4* | −4 ± 1.8
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | 12 mo HDL baseline | 43 ± 4 | 40 ± 5
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | HDL change 12 mo | −2 ± 0.5 | +2 ± 0.4
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | TG baseline | 160 ± 18 | 149 ± 10
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | TG change 12 mo | −22 ± 11.6 | +2 ± 0.8
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | * p < 0.05, perindopril vs. candesartan 6-mo and 1-mo posttreatment followup data also reported 9) Progression to type 2 diabetes: All already have type 2 diabetes 10) Markers of carbohydrate metabolism/diabetes control: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | | [underlined: Perindopril] | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | HbA1c baseline | 6.4 ± 0.9 | 6.5 ± 1.1
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | HbA1c change | −0.2 ± 0.1 | −0.2 ± 0.1
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | 12 mo Fasting glucose baseline | 155 ± 15 | 160 ± 13
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | Fasting glucose 1 yr | −15 ± 4* | −8 ± 2
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | * p < 0.05, perindopril vs. candesartan 6-mo and 1-mo posttreatment followup data also reported 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | | [underlined: Perindopril] | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | AER/24 hr baseline | 17(10) | 18 (11)
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | AER/24 hr change 12 mo | −8 ± 3.6 | –8 ± 41
Derosa, Cicero, Ciccarelli, et al., 2003 #3140 | | | | | | | 6-mo and 1-mo posttreatment followup data also reported
Eguchi, Kario, and Shimada, 2003 #3150 | Geographical location: Tochigi, Japan Study dates: NR Funding source: NR Interventions: - Candesartan (4–12 mg) (n = 37) - Lisinopril (5–20 mg) (n = 36) Dose titration/co-interventions: Initially, all patients treated with candesartan (4–8 mg) or lisinopril (5–10 mg) (choice of dose not explained). Dosage of candesartan was then increased by 4 mg and dosage of lisinopril by 5–10 mg for 4 wk up to the maximum. If response not satisfactory (BP systolic < 140 and BP diastolic < 90) at 4–8 wk, then trichlormethazide 1-2 mg added. At 12 wk, patients crossed over to the alternative drug as monotherapy, with dose titration and addition of diuretic repeated as above. Study design: RCT, crossover Blinding: - Patients: NR - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 1-week “washout” after randomization Washout period(s): No washout between study periods Duration of treatment: 2 x 12-week treatment periods Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 73 - Began treatment: 73 - Completed treatment: NR - Withdrawals/losses to follow-up: NR; all 12 patients who experienced AEs were “excluded from the study” - Population analyzed = 61 Age: Mean (SD): 69.3 ± 7.4 Median: NR Range: NR Sex (n [%]): Female: 57% Male: 43% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after patient seated for 5 min rest using a standard mercury sphygmomano-meter Mean baseline values for analyzed population (n = 61): DBP: 163 ± 17 SBP: 85 ± 11 Concurrent medications (n [%]): Comorbidities (n [%]): Diabetes 48% Smoker 23% Recruitment setting: Clinic office Inclusion criteria: - Ambulatory, asymptomatic older patients with > 3 visits in a 14- to 28- day period with mean SBP > 150 mm Hg or mean DBP > 90 on > 2 occasions Exclusion criteria: - Serum creatinine > 2.5 mg/dL - Major stroke, congestive heat failure, malignancy or other severe concomitant disease - BP > 180/110 mm Hg on medication - Note: Patients with MI with preserved LV contractility and those with “minor” stroke were not excluded | | | | | 1) Blood pressure: Mean seated trough BP at 12 wk: | | | | | General comments: - Meds taken before randomization (no clear run-in period described): ACEI 41% ARB 6.6% Diuretics 16% Calcium antagonist 64% None 6.6% Quality assessment: Overall rating: Poor Comments: - Protocol not clearly defined, blinding not reported, no washout after period 1 of crossover, imbalance in treatment groups (apparently due to more patients discontinuing lisinopril and not continuing to period 2) - Of the 61 patients analyzed, 35 received candesartan first and 26 lisinopril first - Patients with AEs (n = 12) excluded from efficacy analysis Applicability: - Apparently limited to Japanese patients in a single clinic
Eguchi, Kario, and Shimada, 2003 #3150 | | | | | | | | Candesartan (n = 61) | Lisinopril (n = 61)
Eguchi, Kario, and Shimada, 2003 #3150 | | | | | | | SBP | 148 ± 16 | 144 ± 18
Eguchi, Kario, and Shimada, 2003 #3150 | | | | | | | DBP | 79 ± 11 | 77 ± 9.8
Eguchi, Kario, and Shimada, 2003 #3150 | | | | | | | No significant difference between groups (p- values NR) Other outcomes reported: 24-hr ABPM outcomes 2) Rate of use of a single antihypertensive agent for BP control: Trichlormethazide added per protocol: Candesartan: 79% Lisinopril: 80% p = NS
Eguchi, Kario, and Shimada, 2003 #3150 | | | | | | | 3) Mortality: NR 4) Morbidity: NR 5) Safety: Patients with AEs requiring their “exclusion” from analysis: Candesartan: 2 patients (2.7%; 1 dim vision and 1 facial edema) Lisinopril: 10 patients (13.7%; 9 cough, 2 fatigue) (numbers given here as reported) 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | Geographical location: North America, Europe, and South Africa Study dates: NR Funding source: SmithKline Beecham Pharma (Collegeville, PA; since merged with GlaxoSmithKline, now GSK) Interventions: - Enalapril 5 mg qd, with titration up to 20 mg qd (n = 264) - Eprosartan 200 mg bid, with titration up to 300 mg bid (n = 264) Both groups: HCTZ 12.5–25 mg qd added at 12 wk if DBP ≥ 90) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes (titration/maint) - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 5-wk single-blind placebo run-in Duration of treatment: 26 wk: 18-wk titration period + 8-wk maintenance period Duration of post-treatment followup: None | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 528 - Began treatment: NR - Completed treatment: 447 - Withdrawals/losses to followup: NR (≥ 16) Age: Mean (± SEM): 55.6 ± 0.7 Median: NR Range: 23–84 Sex (n [%]): Female: 56.5% Male: 43.5% Race/ethnicity (n [%]): Caucasian 456 (86%) Black 40 (8%) Asian 6 (1%) Other 26 (5%) Baseline blood pressure (± SEM); Sitting BP measured in triplicate “according to standard techniques” DBP | | | | | 1) Blood pressure: Mean post-treatment BP values NR [underlined: Overall study population] Mean change in BP from baseline (at 26 wk): | | | | | General comments: - An analysis comparing the subgroups < 65 years and ≥ 65 years of age found that the elderly subpopulation “mirrored the response of the study as a whole” - An analysis of a subgroup of 40 black patients found that the black subpopulation “mirrored the response of the study as a whole” Quality assessment: Overall rating: Fair Comments: - Method of BP ascertainment not described - Uncertainty about number of withdrawals (enumerated those w/d for serious AE and cough; but not for any other causes, if any) - One report described 529 patients instead of 528; other minor discrepancies across reports Applicability: - No list of participating centers (described as multinational) - Poor description of subjects’ comorbidities, although exclusion criteria suggest a comparatively healthy group
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | [underlined: Enalapril] | [underlined: Eprosartan] | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | SBP | 156.2 ± 0.9 | 156.4 ± 0.9 | | | Sit SBP | −14.7 | −15.5 mm Hg
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | DBP | 101.2 ± 0.3 | 100.7 ± 0.3 | | | Sit DBP | −11.9 | −12.9 mm Hg
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | Baseline values also reported for ≥ 65 years subgroup and black subgroup Concurrent medications (n [%]): NR; concomitant use of medications know to affect BP prohibited Comorbidities (n [%]): Current smoker: Enalapril: 31 (12%) Eprosartan: 36 (14%) See also Exclusion criteria, below Recruitment setting: NR Inclusion criteria: - Age ≥ 18 yr - Essential HTN (sitting DBP 95-114 mm Hg) Exclusion criteria: - Secondary forms of hypertension - Advanced hypertensive retinopathy - Sitting SBP > 200 mmHg - MI or CVA < 90 days - CHF or angina - Advanced AV conduction defects, ventricular tachyarrhythmias, bradycardia - Unstable DM - Clinically significant renal or hepatic disease - Other concurrent severe disease - Emphysema, chronic bronchitis, asthma with cough, URI < 2 wks | | | | | Response rates (DBP < 90 or DBP < 100 and a reduction of ≥ 10 mm Hg from baseline):
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 12 wk | 62.6% | 70.3% (p < 0.05)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 26 wk | 73.4% | 81.7% (p < 0.02)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | [underlined: ≥ 65 years subgroup] Mean change in BP from baseline (at 26 wk):
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Sit SBP | −15.3 ± 2.2 | −18.9 ± 2.1 (NS)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Sit DBP | −12.2 ± 1.1 | −13.9 ± 1.1 (NS)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Response rates:
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 26 wk | 48 (77.4%) | 55 (87.3%) (NS)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | [underlined: Black patient subgroup] Mean change in BP from baseline (at 26 wk):
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Sit SBP | −10.5 ± 3.7 | −18.8 ± 3.5 (NS)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Sit DBP | −9.6 ± 2.4 | −10.5 ± 1.9 (NS)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Response rates:
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 12 wk | 5 (26.3%) | 11 (52.4%) (p < 0.05)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 26 wk | 8 (42.1%) | 14 (66.7%) (p = 0.02)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Eprosartan group: HCTZ added in 81 patients Enalapril group: HCTZ added in 81 patients 3) Mortality: One death in eprosartan group; judged to be unrelated Morbidity: One MI in eprosartan group, judged to be unrelated to treatment. The between-group differences in changes in Psychological General Well Being (PGWB) scores were -2.48 (95% CI −4.63 to −0.32) for the study end point and −0.79 (−2.72 to 1.15) for monotherapy end point. At monotherapy end point there were no significant differences between treatments (data not presented). 5) Safety:
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Severe AE | 32 (12.1%) | 24 (9.1%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Tx-related | 16 (6.1%) | 10 (3.8%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Serious nonfatal | 8 (3.0%) | 4 (1.5%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | ≥1 AE | 213 (80.7%) | 201 (76.1%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | ≥ 65 years subgroup
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | All AE | 48 (77.4%) | 46 (73.0%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | All Serious | 7 (11.3%) | 4 (6.3%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Serious - w/d | 1 | 1
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Serious - no w/d | 3 | 0
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 6) Specific adverse events:
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | [underlined: Enalapril] | [underlined: Eprosartan]
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Definite cough | 14 (5.4%) | 4 (1.5%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Cough (p = 0.01) | 59 (22.3%) | 34 (12.9%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Pharyngitis | 64 (24.2%) | 44 (16.7%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Headache | 37 (14.0%) | 39 (14.8%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Rhinitis | 43 (16.3%) | 33 (12.5%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | URI | 43 (16.3%) | 33 (12.5%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Myalgia | 16 (6.1%) | 25 (9.5%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Dyspnea | 17 (6.4%) | 14 (5.3%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Dizziness | 21 (8.0%) | 13 (4.9%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | Fatigue | 18 (6.8%) | 13 (4.9%)
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | *definite cough – persistent, non-productive (dry) cough assoc. with tx and not due to URI as judged by investigator 7) Persistence/adherence: NR 8) Lipid levels:
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | | Eprosartan baseline end | | Enalapril baseline end
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | LDL-c | 3.5±0.8 | 3.6±0.9 | 3.5±0.9 | 3.7±0.9
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | HDL-c | 1.4±0.3 | 1.4±0.4 | 1.4±0.4 | 1.4±0.3
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | TG | 1.6±1.0 | 1.6±1.1 | 1.6±1.0 | 1.7±1.1
Elliott, 1999 #5950 and Gavras and Gavras, 1999 #6030 and Levine, 1999 #6020 and Argenziano and Trimarco, 1999 #6040 and Breeze, Rake, Donoghue, et al., 2001 #4660 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: “Neither eprosartan nor enalapril significantly affected … blood glucose” at any time point. 11) LV mass/function: NR 12) Creatinine/GFR: “The degree and direction of … renal function tests were comparable in both treatment groups.” 13) Proteinuria: NR
Erkens, Panneman, Klungel, et al., 2005 #12840 | Geographical location: 25 medium-sized cities in The Netherlands Study dates: Included patients received treatment between 1997 and 2001 Funding source: Novartis Pharma, B.V. (The Netherlands) Interventions: Diuretics (n = 458) Beta-blockers (n = 471) CCBs (n = 455) ACEIs (n = 412) ARBs (n = 447) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Patients followed for 15 mo after their index data | Number of patients: - Screened for inclusion: 48,234 - Eligible for inclusion: 2243 (after random selection of 500 per group and post-selection exclusions) - Randomized: NA - Began treatment: NA - Completed treatment: NA - Withdrawals/losses to followup: NA Age: Mean (SD): NR Median: NR Range: - 0-19: 1.6% - 20-39: 11.5% - 40-59: 42.6% - 60-79: 37.0% - ≥ 80: 7.4% Sex (n [%]): Female: 1276 (56.9%) Male: 967 (43.1%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): Antidiabetic drugs: 11.3% Lipid-lowering drugs: 9.4% Antiasthmatic drugs: 14.2% Comorbidities (n [%]):Prior CV hospitalizations: 8.2% Recruitment setting: - Data drawn from community-based database linking drug-dispensing records from pharmacies and hospital discharge records - Patients receive first antihypertensive prescription from GP (85%), internist (5.8%), cardiologist (4.0), or other (5.2%) Inclusion criteria: - From base cohort (n = 48,234), patients selected who: (1) did not use antihypertensive drugs in the year before the index date; (2) were registered in the database for ≥ 1 yr before and ≥ 15 mo after their first prescription for antihypertensive drugs; and (3) received at least two prescriptions for antihypertensive drugs - From this group, 500 per drug class randomly drawn for analysis Exclusion criteria: Patients using fixed combination drugs | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: 1-yr persistence (defined as the % of patients who used a given drug for ≥ 270 days and had an additional drug dispensing in the 3 mo after the followup period): | | | | | General comments: - High-quality administrative data in a population-based sample Quality assessment: Overall rating: Fair Comments: - Non-random allocation to drugs - No data on comparability of patients on ACEIs versus ARBs - Funded by pharmaceutical company Applicability: - Specific ACEIs and ARBs not identified
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | Diuretics: | 33.0%
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | Beta-blockers: | 35.0%
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | CCBs: | 34.7%
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | ACEIs: | 59.7%
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | ARBs: | 62.0%
Erkens, Panneman, Klungel, et al., 2005 #12840 | | | | | | | Persistence increased with male sex, increasing age, use of antidiabetic drugs, use of lipid- lowering drugs, and prior cardiovascular hospitalizations (all in univariable analyses) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | Geographical location: NR Pavia, Italy Study dates: NR Funding source: NR Interventions: - Perindopril 4 mg daily (n = 42) - Losartan 50 mg daily (n = 43) No dose titration; no co-interventions specified Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 85 - Began treatment: 85 - Completed treatment: 82 - Withdrawals/losses to followup: 3 (2 due to AEs, 1 failure to appear at visit) Age: Mean (SD): 58.4 (8.0) Median: NR Range: 46-64 Sex (n [%]): Female: 40 (47%) Male: 45 (53%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP assessed using a standard mercury sphygmanometer; 3 readings taken at 1-min intervals after patient rested 10 min; average of 3 readings used | | | | | 1) Blood pressure: Mean trough seated BP at 12 wk: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Numbers screened and eligible NR - AEs not well reported - Details of dose titration and concomitant med use (if any) not given Applicability: - 100% of study population also has type 2 diabetes - Racial diversity not described (?100% Caucasian) - Recruitment setting(s) not described - 44 patients never treated before for hypertension
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | [underlined: Perindopril] | [underlined: Losartan] | | | | [underlined: Perindopril] | [underlined: Losartan]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | SBP | 163.2 ± 12.9 | 162.9 ± 12.6 | | | SBP | 146 ± 10 | 147 ± 11
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | DBP | 102.8 ± 6.1 | 102.7 ± 5.9 | | | DBP | 87 ± 5 | 88 ± 5
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | Concurrent medications (n [%]):NR Comorbidities (n [%]):100% type 2 diabetes Recruitment setting: NR Inclusion criteria: - Adult men and women - Documented mild-to-moderate essential HTN (DBP 90–110) - Concomitant type 2 diabetes in stable metabolic control with diet and oral hypoglycemic agents Exclusion criteria: - Secondary HTN - Previous or active ischemic heart disease - Serum creatinine > 1.5 mg/dL - Chronic liver disease - Obesity (BMI >28) - Pregnancy | | | | | p = 0.001 for all pre-/post- comparisons p = NS for between-treatment comparisons Mean change in BP at 12 wk:
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Perindopril] | [underlined: Losartan]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | SBP | −16 | −15
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | DBP | −15 | −14
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | p < 0.001 for all pre-/post- comparisons p = NS for between-treatment comparisons 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: 2 withdrawals due to AEs – treatment group(s) not specified 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean HDL (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 44 ± 5 | 46 ± 6 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 44 ± 5 | 44 ± 6 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Mean total cholesterol (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 197 ± 23 | 186 ± 19 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 191 ± 20 | 188 ± 19 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Mean triglycerides (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 142 ± 49 | 127 ± 44 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 145 ± 50 | 140 ± 48 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean FBG (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 112 ± 7.3 | 107 ± 6.9 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 113 ± 7.5 | 111 ± 7.0 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Mean HbA1c (%):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 7.2 ± 1.9 | 7.1 ± 1.7 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 6.9 ± 2.0 | 7.0 ± 1.8 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: Mean serum creatinine (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Perindopril | 1.1 ± 0.4 | 1.1 ± 0.4 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | Losartan | 1.1 ± 0.5 | 1.1 ± 0.4 | NS
Fogari, Mugellini, Zoppi, et al., 2002 #4320 | | | | | | | 13) Proteinuria: NR
Fogari, Mugellini, Zoppi, et al., 2004 #2490 | Geographical location: NR (authors based in Pavia, Italy) Study dates: NR Funding source: NR Interventions: - Valsartan 160 mg (n = 75) - Enalapril 20 mg (n = 75) No dose titration; no co-interventions permitted Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk run-in; previous anti-HTN treatment withdrawn Duration of treatment: 16 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 150 - Began treatment: 150 - Completed treatment: 140 - Withdrawals/losses to followup: 6 (2 due to lack of compliance, 3 due to missed clinic visit, and 1 due to concomitant illness) Age: Mean (SD): 70.3 ± 5.7 Median: NR Range: NR Sex (n [%]): Female: 79/144 (54%) Male: 65/144 (46%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomano- meter after patient rested in sitting position for 5 min; mean of 3 measurement taken at 2-min intervals used | | | | | 1) Blood pressure: Trough seated BP at 16 wk: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Not everyone blinded - No titration for increase blood pressure Applicability: - Many comorbidities excluded in this elderly population and again comorbidities not presented - No data on race/ethnicity of subjects
Fogari, Mugellini, Zoppi, et al., 2004 #2490 | | | [underlined: Valsartan] | [underlined: Enalapril] | | | | Valsartan (n = 73) | Enalapril (n = 71) | P-value
Fogari, Mugellini, Zoppi, et al., 2004 #2490 | | SBP | 165.9 ± 7.3 | 165.8 ± 6.8 | | | SBP | 147.3 ± 7.3 | 150.2 ± 8.0 | < 0.01
Fogari, Mugellini, Zoppi, et al., 2004 #2490 | | DBP | 100.8 ± 3.7 | 100.9 ± 3.9 | | | DBP | 87.1 ± 4.7 | 90.4 ± 5.0 | < 0.001
Fogari, Mugellini, Zoppi, et al., 2004 #2490 | | Concurrent medications (n [%]): NR; concomitant drugs with antihypertensive properties prohibited Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics Inclusion criteria: Outpatients 61–80 years of age with mild-moderate hypertension (DBP ≥95 and ≤ 110) at end of 2-wk run-in Exclusion criteria: - Secondary arterial hypertension, sitting systolic blood pressure > 200, malignant hypertension, K_W retinopathy III or IV, a hx of HTN encephalopathy - CVA within 6 months, previous or current heart failure, MI within 6 months, angina, valvulopathy or relevant arrythmia - Hepatic or renal dysfunction - Clinical hypo or hyperthyroidism - Known hypersensitivity to ACEI or ARB | | | | | BP normalized at 16 wk (DBP < 90 mm Hg): Valsartan: 60.2% Enalapril: 52.1% p = NS 2) Rate of use of a single antihypertensive agent for BP control: See immediately above on % of patients who normalized at 16 wk on monotherapy. 3) Mortality: NR4) Morbidity: NR 5) Safety: Any AE: Valsartan: 5 (6.8%) Enalapril: 9 (12.6%) No serious AEs that were considered to be drug- related 6) Specific adverse events: Cough n = 4 enalapril and n = 1 valsartan HA V = 2 and E = 2 Nausea V = 1 E = 2 7) Persistence/adherence: “Patient compliance to both treatments was satisfactory” (no quantitative data reported) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Fogari, Zoppi, Preti, et al., 2001 #4790 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions: - Trandolapril 2 mg daily (n = 45) - Losartan 50 mg daily (n = 44) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in period Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 89 - Began treatment: 89 - Completed treatment: 89 - Withdrawals/losses to followup: NA Age: Mean (SD): 55.5 (2) Median: NR Range: 51-60 Sex (n [%]): Female: 89 (100%) Male: 0 Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a standard mercury sphygmanometer; mean of 3 readings at 1-min intervals after 10 min rest | | | | | 1) Blood pressure: Mean trough seated BP at 12 wk: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Numbers screened and eligible NR - AEs not well reported - Details of dose titration and concomitant med use (if any) not given Applicability: - 100% of study population post- menopausal women - Racial diversity not described (?100% Caucasian) - Recruitment setting(s) not described
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | [underlined: Trandolapril] | [underlined: Losartan] | | | | [underlined: Trandolapril] | [underlined: Losartan]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | SBP | 162.1 ± 12 | 160.6 ± 12 | | | SBP | 145.2 ± 10 | 145.5 ± 11
Fogari, Zoppi, Preti, et al., 2001 #4790 | | DBP | 101.2 ± 5 | 100.5 ± 5 | | | DBP | 88.1 ± 4 | 88.6 ± 5
Fogari, Zoppi, Preti, et al., 2001 #4790 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Mild-moderate essential HTN (DBP 90–110 mm Hg - Postmenopausal women (defined by cessation of menses ≥ 1yr; confirmed by: (1) plasma FSH > 20 U/L; (2) FSH > LH levels; and (3) plasma 17-β-estradiol < 50 pmol/L) Exclusion criteria: - Hormone replacement therapy < 6 mo - Diabetes mellitus, obesity, smoking, MI, or stroke < 6 mo - History of breast cancer or thromboembolic disease - Major systemic diseases - Any condition that would require use of concomitant medications | | | | | p < 0.01 for all pre-/post- comparisons p = NS for between-treatment comparisons Mean change in BP at 12 wk:
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Trandolapril] | [underlined: Losartan]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | SBP | −17 | −15
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | DBP | −13 | −12
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | p < 0.01 for all pre-/post- comparisons p = NS for between-treatment comparisons 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean HDL (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Trandolapril | 50 ± 15 | 50 ± 16 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Losartan | 49 ± 16 | 48 ± 17 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Mean total cholesterol (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Trandolapril | 231 ± 31 | 226 ± 29 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Losartan | 227 ± 33 | 224 ± 31 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Mean triglycerides (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Trandolapril | 128 ± 59 | 125 ± 57 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Losartan | 120 ± 51 | 123 ± 50 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean FBG (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Trandolapril | 92 ± 10 | 89 ± 10 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Losartan | 93 ± 9 | 92 ± 10 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Mean glucose infusion rate (GIR) (mg/min/kg):
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | | [underlined: Baseline] | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Trandolapril | 6.67 ± 0.56 | 7.99 ± 0.65 | < 0.05
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | Losartan | 6.74 ± 0.47 | 6.96 ± 0.50 | NS
Fogari, Zoppi, Preti, et al., 2001 #4790 | | | | | | | p = significant (but not specified) for between- group comparison 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Franke, 1997 #11930 | Geographical location: Saarlouis, Germany Study dates: NR Funding source: NR Interventions: - Placebo (n = 65) - Candesartan 4 mg (n = 66) - Candesartan 8 mg (n = 68) - Candeartan 12 mg (n = 65) - Enalapril 10 mg (n = 71) No dose titration; no co-interventions Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: Washout of at least 2 weeks, followed by 2-week placebo run-in Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 364 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR (11 due to AEs, rest uncertain) - ITT population = 335 Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): NR Race/ethnicity (n [%]): NR Baseline blood pressure: NR Seated trough BP measured using a fully automated device (Bosotron 2) Baseline values NR Concurrent medications (n [%]): NR; concomitant treatment with other antihypertensives not permitted Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age 18-70 yr - Mild-to-moderate essential hypertension (sitting DBP 95-114 mmHg) Exclusion criteria: None specified | | | | | 1) Blood pressure: Baseline BP values NR (except DBP in Figure 1) Mean post-treatment BP values NR Mean changes (± SD) in seated trough DBP (mm Hg) at 12 wk: Candesartan 4 mg (n = 66): −8.4 ± 10.5 Candesartan 8 mg (n = 68): −10.5 ± 9.9 Candesartan 12 mg (n =65): −10.0 ± 10.0 Enalapril 10 mg (n = 71): −10.6 ± 9.8 No between-group statistical results shown Response rates (reduction in seated DBP of ≥ 10 mm Hg and/or seated DBP < 90 mm Hg): Candesartan 4 mg (n = 66): 53.0% Candesartan 8 mg (n = 68): 69.1% Candesartan 12 mg (n =65): NR Enalapril 10 mg (n = 71): 69.0% No between-group statistical results shown 2) Rate of use of a single antihypertensive agent for BP control: No other antihypertensives permitted 3) Mortality: NR 4) Morbidity: NR 5) Safety: 186 adverse events, equally distributed among all groups Patients experiencing ≥ 1 AE: Candesartan groups: 28-33% Enalapril: 35% Withdrawals due to AEs: 11 (treatment groups not specified) 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | General comments: - Short report with minimal details Quality assessment: Overall rating: Poor Comments: - Extremely brief, few details Applicability: - Minimal information provided about study population, recruitment sites, etc.
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | Geographical location: NR Study dates: June 1999-Dec 2001 Funding source: NR Interventions: Multi-therapy trial (nifedipine, amlodipine, atenolol, nebivolol, telmisartan, and perindopril); total study was 40 normotensive controls and 180 treated patients - Telmisartan 80 to 160 mg (n = 29) - Perindopril 2 to 4 mg (n = 28) HCTZ 12.5 mg added if needed to each compound Study design: RCT, parallel-group Blinding: - Patients: NR - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 180 - Began treatment: 180 - Completed treatment: 168 - Withdrawals/losses to followup: 12, all due to treatment failure (required additional drugs beyond those specified in study protocol) Age: Mean (SD): 50.5 ± 10 Median: NR Range: NR Sex (n [%]): Female: 22/57 = 37% Male: 36/57 = 63% Race/ethnicity (n [%]): NR Baseline blood pressure: Mean of 3 measurements taken at 3- min intervals using an automatic digital device (Omron HEM-705CP) | | | | | 1) Blood pressure: At 6 months: | | | | | General comments: - Patients in multiple arms with small control group Quality assessment: Overall rating: Poor Comments: - No comment on blinding of endpoints - Study population not well defined (how they were recruited, which patients from which groups dropped out, etc.) - No data on race/ethnicity of subjects - No data on safety/adverse events Applicability: - Limited by few comorbidities and multiple comparisons
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | [underlined: Telmisartan] | [underlined: Perindopril] | | | | [underlined: Telmisartan] | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | SBP | 151 ± 10 | 153 ± 9 | | | SBP | 133 ± 10 | 134 ± 10
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | DBP | 100 ± 7 | 100 ± 6 | | | DBP | 86 ± 5 | 86 ± 6
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | Concurrent medications (n [%]):NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics Inclusion criteria: - Patients with essential hypertension who were never treated or had discontinued treatment for HTN - Non-smokers or < 5 cigarettes per day - Alcohol consumption < 50 mg/day Exclusion criteria: - Diabetes - Renal dysfunction - Total cholesterol > 240 | | | | | Responders at 6 mo (BP < 140/90 mm Hg): Telmisartan: 22/29 (76%) Perindopril: 22/28 (79%) 2) Rate of use of a single antihypertensive agent for BP control: HCTZ added in 21% of telmisartan patients (6/29) and 25% of perindopril patients (7/28) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: 164 out of 180 – 16 BP rose too high to continue in study protocol 8) Lipid levels: Total cholesterol:
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | | [underlined: Telmisartan] | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | Baseline | 218 ± 24 | 214 ± 252
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 6 mo | 216 ± 21 | 209 ± 21
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | HDL:
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | | [underlined: Telmisartan] | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | Baseline | 53 ± 15 | 53 ± 11
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 6 mo | 52 ± 14 | 53 ± 9
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | LDL:
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | | [underlined: Telmisartan] | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | Baseline | 136 ± 16 | 131 ± 18
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 6 mo | 134 ± 17 | 128 ± 15
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 9) Progression to type 2 diabetes: Plasma glucose levels remained essentially unchanged (see immediately below) 10) Markers of carbohydrate metabolism/diabetes control: Plasma glucose:
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | | [underlined: Telmisartan] | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | Baseline | 97 ± 8 | 96 ± 7
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 6 mo | 97 ± 8 | 97 ± 5
Ghiadoni, Magagna, Versari, et al., 2003 #3330 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Gregoire, Moisan, Guibert, et al., 2001 #5090 | Geographical location: 173 pharmacies across Canada Study dates: Feb 1996-Oct 1997 Funding source: Merck Frosst Canada Interventions: - Losartan (n = 80) - ACEI (n = 369) - CCB (n = 214) Study design: Prospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes (research assistants unaware of study’s objectives telephoned participants) Was allocation concealment adequate?: NR Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: 3 months (assessments at baseline, 1mo, and 3mo) | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: NA - Began treatment: 692 recruited - Completed treatment: 663 - Withdrawals/losses to followup: 29 (9 lost to followup, 20 discontinued before end of study for reasons other than AEs) Age: Mean (SD): 58.3 Median: NR Range: 20.4-87.7 Sex (n [%]): Female: 369 (55.7%) Male: 294 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]):NR Comorbidities (n [%]): NR Recruitment setting: 173 pharmacies in Canada Inclusion criteria: - HTN patients ≥ 18 yr - Received 1^st^ prescription for losartan, ACEI, or CCB as hypertensive monotherapy Exclusion criteria: - Pregnant women - Taking other anti-HTN meds - Taking meds for CHF or angina - Previously given samples of study medication by their physicians | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: ≥ 1 AE related to antihypertensive medication: Losartan: 42/80 (52.5%) ACEI: 222/369 (60.2%) CCB: 149/214 (69.6%) Odds of reporting an AE were significantly higher among patients treated with an ACEI (adjusted odds ratio = 1.78; 95% CI, 1.02 to 3.12) or a CCB (2.65; 1.47 to 4.78) than among patients treated with losartan. Estimates adjusted for age, sex, level of education, number of symptoms due to health problems pereived the week prior to entering the study, prior use of antihypertensive drugs, current use of any other medication, insurance coverage, and duration of hypertension). 6) Specific adverse events: Specific AEs (numbers are n [%]): | | | | | General comments: - Obvious limitations from prospective cohort design with no info on those screened but not included - Statistically significant differences at baseline between 3 groups with respect to proportion who were “new users” vs. “discontinuers” and numbers who switched previous medication due to AEs and uncontrolled hypertension - No data on BP Quality assessment: Overall rating: Poor Comments: - Numbers screened and eligible NR - AEs relatively well reported - Adjustment generally good, but lacks adjustment for comorbid conditions (e.g., CHF) which could confound presence of AEs Applicability: - No assessment of severity of disease or comorbidities - No adjustment or evaluation for comorbitiies or severity of disease - Patients selected by pharmacies - No blood pressure data
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | | [underlined: Losartan] | [underlined: ACEI] | [underlined: CCB]
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Dizziness | 16 (20) | 49 (13.3) | 51 (23.8)
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Headache | 11 (13.8) | 53 (14.4) | 49 (22.9)*
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Dry cough | 4 (5.0) | 55 (14.9)* | 5 (2.3)
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Tiredness | 4 (5.0) | 23 (6.2) | 15 (7.0)
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Nausea | 2 (2.5) | 19 (5.1) | 17 (7.9)*
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Dry mouth | 4 (5.0) | 19 (5.1) | 11 (5.1)
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | Swollen ankles | 2 (2.5) | 1 (0.3) | 27 (12.6)*
Gregoire, Moisan, Guibert, et al., 2001 #5090 | | | | | | | * Adjusted odds of experiencing AE significantly greater than with losartan (see Table 3 for details) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Hasford, Mimran, and Simons, 2002 #4090 | Geographical location: France, Germany, and UK Study dates: Initial antihypertensive prescription given Oct 1997–Sep 1998; patients followed retrospectively for 1 yr Funding source: Sanofi-Synthelabo and Bristol-Myers Squibb Interventions: Monotherapy with one of the following single agents: - ACEIs: 333 - Irbesartan: 380 - Losartan: 188 - Valsartan: 69 - Candesartan: 82 - Eprosartan: 35 - Beta-blockers (BBs): 441 - Calcium channel blockers (CCBs): 466 - Diuretics: 422 Dose titration and co-interventions: Dose titration of initial medication allowed Study design: Retrospective cohort database study Matched those initially not prescribed irbesartan to those prescribed irbesartan by diabetes, angina, CVA, CHF, MI Blinding - Patients: NA - Providers: NA - Assessors of outcomes: NA Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 1-yr follow up after identification Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 3026 - Eligible for inclusion: 2416 - Randomized: NA - Began treatment: NA - Completed treatment: NA - Withdrawals/losses to followup: NR Age: Mean (SD): 60.3 Median: NR Range: NR Sex (n [%]): Female: 1269 (54%) Male: 1147 (46%) Race/ethnicity (n [%]): NR, presumably 100% Caucasian Baseline blood pressure: Method of assessing BP not described | | | | | 1) Blood pressure: BP reduction not a predefined study outcome Minimal results reported for subgroup of all patients with on-treatment BP data (n = 717); precise timepoint(s) of BP measurement(s) not specified; not clear whether restricted to patients who persisted with their original monotherapy General estimating equation (GEE) analysis showed that, in above-described subgroup, patients who were originally prescribed irbesartan had a greater average decrease in SBP (5.91 mm Hg; p = 0.053) and DBP (4.10 mm Hg; p = 0.090) than patients who were initially prescribed losartan and a greater average decrease in SBP (4.95 mm Hg; p = 0.022) and DBP (3.59 mm Hg; p = 0.053) than patients who were initially prescribed any of the remaining agents 2) Rate of use of a single antihypertensive agent for BP control: Assessed on basis of prescriptions filled By 1 yr: 46.8% persisted with initially prescribed monotherapy (see below, under Persistence/adherence) 12.9% (9% irbesartan, 8% losartan, 13.6% all other agents) had switched to a different single agent 23.8% had been prescribed adjunctive antihypertension treatment in addition to initially prescribed med (16.1% irbesartan, 24.5% losartan, 25.3% all other agents) 3) Mortality: NR 4) Morbidity: NR 5) Safety: 12.9% overall (9% irbesartan, 8% losartan, 13.6% all other agents) switched to another agent and 16.5% (14.2% irbesartan, 22.9% losartan, 16.6% all other agents) discontinued all antihypertensive therapy , but not clear whether this had to do with efficacy or AEs or something else 6) Specific adverse events: NR 7) Persistence/adherence: Persistence status determined on basis of filled prescriptions See outcome 2, above, for overall persistence rates Persistence by treatment group (defined as percentage of patients who remained on their initially prescribed monotherapy at 1 yr): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Does not report those who were lost from the system at 1 yr - Outcome measured not useful (lumped together multiple reasons for not being on monotherapy after 1 yr) Applicability: - Does not report prevalence of the comorbidities patients were matched on (diabetes, angina, CVA, CHF, MI)
Hasford, Mimran, and Simons, 2002 #4090 | | | [underlined: SBP] | [underlined: DBP] | | | | [underlined: Persistence]
Hasford, Mimran, and Simons, 2002 #4090 | | ACEIs | 159.8 ± 22.5 | 94.6 ± 14.1 | | | ACEIs | 42%
Hasford, Mimran, and Simons, 2002 #4090 | | Irbesartan | 164.3 ± 22.4 | 93.5 ±16.7 | | | Irbesartan | 60.8%*
Hasford, Mimran, and Simons, 2002 #4090 | | Losartan | 160.4 ± 19.5 | 91.4 ± 13.8 | | | Losartan | 44.7%
Hasford, Mimran, and Simons, 2002 #4090 | | Other ARBs | 164.7 ± 21.8 | 95.9 ± 20.6 | | | Other ARBs | 51.3%
Hasford, Mimran, and Simons, 2002 #4090 | | BBs | 162.2 ± 23.6 | 94.4 ± 14.4 | | | BBs | 49.7%
Hasford, Mimran, and Simons, 2002 #4090 | | CCBs | 162.9 ± 22.1 | 93.6 ± 17.5 | | | CCBs | 43.6%
Hasford, Mimran, and Simons, 2002 #4090 | | Diuretics | 160.7 ± 20.4 | 93.8 ± 12.6 | | | Diuretics | 34.4%
Hasford, Mimran, and Simons, 2002 #4090 | | Concurrent medications (n [%]):NR Comorbidities (n [%]):NR Recruitment setting: Database study from a health database maintained in UK, France, and Germany that covers “hundreds” of practices that “represent the characteristics of the general medicine practices in each country” Inclusion criteria: - Newly diagnosed hypertension (< 1 yr) - Initial therapy with single agent Exclusion criteria: - Hypertension > 1 yr - Initial prescription for dual agents | | | | | * p ≤ 0.001 for irbesartan vs. diuretics, ACEIs, CCBs, BBs, and losartan; p ≤ 0.009 for irbesartan vs. other ARBs 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Karlberg, Lins, and Hermansson, 1999 #6090 | Geographical location: 22 sites, 2 Denmark, 6 Finland, and 14 Sweden Study dates: NR Funding source: NR Interventions: - Telmisartan (20, 40–80 mg) (n = 139) - Enalapril (5, 10–20 mg) (n = 139) Titrated to higher dose if mean DBP > 90 at 4-wk intervals until wk 16, then add HCTZ 12.5–25 mg for DBP > 90 Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 5-wk double-dummy placebo run-in period to determine eligibility Duration of treatment: 26 wk: 16 wk titration; 10 wk maintenance Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: 356 - Eligible for inclusion: NR - Randomized: 278 - Began treatment: 278 - Completed treatment: 251 - Withdrawals/losses to followup: 36, 2 due to lack of efficacy, 27 due to AEs, 7 for administrative or other reasons (note: reported numbers do not total correctly) - ITT population = 272 Age: Mean (SD): 71.0±4.9 Median: NR Range: NR Sex (n [%]): Female: 160 (58%) Male: 118 (42%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough BP measured 3 times at 2- min intervals after patient rested in supine position for 5 min using a standard mercury sphygmo- manometer Baseline supine values: | | | | | 1) Blood pressure: Placebo-adjusted mean change from baseline in trough supine BP (mm Hg; means NR): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: Applicability: - No real baseline comorbidity information - Recruitment strategy not clear, run in period took 20% out - No data on race/ethnicity of subjects
Karlberg, Lins, and Hermansson, 1999 #6090 | | | [underlined: Telmisartan] | [underlined: Enalapril] | | | | Telmisartan | Enalapril | p-value
Karlberg, Lins, and Hermansson, 1999 #6090 | | SBP | 180.6 ± 18.4 | 177.4 ± 16.6 | | | SBP | −22.1 | −20.1 | 0.350
Karlberg, Lins, and Hermansson, 1999 #6090 | | DBP | 101.9 ± 5.2 | 100.7 ± 5.1 | | | DBP | −12.8 | −11.4 | 0.074
Karlberg, Lins, and Hermansson, 1999 #6090 | | Concurrent medications (n [%]): Outside of HCTZ added per protocol, not assessed or mentioned Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR – assume outpatient clinics Inclusion criteria: - Age ≥ 65 years with mild to moderate HTN - Mean DBP ≥ 95 and ≤ 114 mmHg at final two consecutive visits of the 3- to 5-wk placebo run-in phase, and if mean supine DBP vary by more than 10 mmHg Exclusion criteria: - Known or suspected secondary hypertension - Hepatic or renal dysfunction - Bilateral renal artery stenosis or post-renal transplant - NYHA class III or IV CHF - Recent MI or CABG - Clinically relevant arrhythmias - Clinically significant sodium depletion - Hypokalemia or hyperkalemia - Poorly controlled diabetes - Chronic use of oral anti-coagulants - High doses NSAIDs or acetaminophen - Salt substitutes or KCL - Use of investigational drugs - Patients with mean supine SBP > 220 or supine DBP > 114 mm Hg at any time during the placebo run-in phase | | | | | Response rates (trough supine BP, last available assessment):
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Definition of [underlined: “response”] | [underlined: Telmisartan] | [underlined: Enalapril]
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | DBP < 90 | 86 (63%) | 84 (62%)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | DBP < 90 or decrease ≥ 10 mm Hg vs. baseline | 96 (71%) | 93 (68%)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | SBP reduced ≥ 10 mm Hg vs. baseline | 95 (70%) | 91 (67%)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Note: Also reports subgroup analyses for: - Age < 75 vs. ≥ 75 - Male vs. female Results also reported for ABPM 2) Rate of use of a single antihypertensive agent for BP control: 87 (64%) telmisartan and 84 (63%) enalapril used one agent 3) Mortality: NR 4) Morbidity: Quality of life scales administered, but simply states scores were high at baseline in both groups and did not change during study; no quantitative data 5) Safety: 98/139 patients in each treatment group (71%) experienced ≥ 1 AE. 35 (35%) in the telmisartan group and 52 (37%) in the enalapril group were considered by investigators to have treatment- related AEs. Serious AEs considered by investigators to be treatment-related (number of patients): Telmisartan: - Glaucoma (1) - Strabismus (1) Enalapril: - Dizziness, vertigo and chest pain (1) - Constipation (1) - Stroke (1) - Severe disabling Quincke’s angioneurotic edema (1) Withdrawals due to AEs: Telmisartan: 11 (7.9%) Enalapril: (11.5%) 6) Specific adverse events: Treatment-related AEs (n [%]; n = 139 each group):
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | | Telmisartan | Enalapril
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Any event | 35 (25.2%) | 52 (37.4%)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Cough | 9 (6.5) | 22 (15.8)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Diarrhea | 6 (4.3) | 3 (2.2)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Dizziness | 4 (2.9) | 4 (2.9)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | HA | 3 (2.2) | 4 (2.9)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Flatulence | 2 (1.4) | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Nausea | 2 (1.4) | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Increased sweating | 2 (1.4) | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Erythematous rash | 2 (1.4) | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Rhinitis | 2 (1.4) | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | Impotence | 2 (1.4) | 1 (0.7)
Karlberg, Lins, and Hermansson, 1999 #6090 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | Geographical location: Trabzon, Turkey Study dates: NR Funding source: NR Interventions: - Losartan 50 mg daily (n = 20) - Fosinopril 10 mg daily (n = 10) Dose titration/co-interventions: Amlodipine 5 mg add at 1 mo if BP ≥ 140/85; titrated up to 10 mg if BP still uncontrolled at 2 mo Study design: RCT, parallel-group (open-label) Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NR Baseline/run-in period: 15-day washout if previously on anti-HTN meds (n = 18) Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: - Eligible for inclusion: 33 - Randomized: 33 - Began treatment: 33 - Completed treatment: 33 - Withdrawals/losses to followup: 0 Age: Mean (SD): 52.9 Median: NR Range: 40–66 Sex (n [%]): Female: 20 (61%) Male: 13 (39%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a sphygmomanometer after a 15-min rest; mean of 3 measurements taken at 5-min intervals | | | | | 1) Blood pressure: Mean seated trough BP at 6 mo: | | | | | General comments: - All patients recommended to be on low-protein diet, ? benefit/ impact Quality assessment: Overall rating: Poor Comments: - Inconsistent use of significant digits raises more general suspicions - Large amounts of missing details Applicability: - Patients poorly characterized - Not clear how many other comorbidities present
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | Losartan | Fosinopril | | | | [underlined: Losartan] | [underlined: Fosinopril]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | SBP | 159 ± 21 | 156 ± 21 | | | SBP | 132 ± 10 | 136 ± 8
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | DBP | 99 ± 11 | 97 ± 9 | | | DBP | 84 ± 7 | 84 ± 4
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | Concurrent medications (n [%]): Usual antidiabetic medication continued during trial: | | | | | All comparisons with baseline statistically significant Between-group p-values NS 2) Rate of use of a single antihypertensive agent for BP control: Patients using adjunctive amlodipine: Losartan: 7 (35%) Fosinopril: 4 (31%) 3) Mortality: No deaths during study 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean total cholesterol (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | Losartan | Fosinopril | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | Oral meds | 13 (65%) | 9 (69%) | | | Losartan | 5.65 ± 1.24 | 5.7 ± 1.25 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | Insulin | 3 (15%) | 2 (15%) | | | Fosinopril | 5.97 ± 1.3 | 5.34 ± 0.72 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | Comorbidities (n [%]): - 100% with diabetes type 2 Recruitment setting: Internal medicine outpatient clinics of a university hospital Inclusion criteria: - Type 2 diabetes - SBP 140–180 Exclusion criteria: - Albuminuria > 300 mg/day - Cr Cl < 100 mlLmin - Taking ACEIs or AT1 blockers | | | | | Mean triglycerides (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan | 2.17 ± 1.1 | 1.66 ± 0.72 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril | 2.36 ± 1.2 | 1.87 ± 1.0 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | 9) Progression to type 2 diabetes: NA 10) Markers of carbohydrate metabolism/diabetes control: Mean total glucose (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan | 8.93 ± 3 | 7.76 ± 1.96 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril | 9.87 ± 3.4 | 9.327 ± 1.9 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Mean HbA1c (%):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan | 7.53 ± 2.50 | 6.58 ± 1.18 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril | 8.15 ± 1.64 | 7.57 ± 1.65 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: Mean creatinine (μmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan | 78.7 ± 17.7 | 84.8 ± 10.6 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril | 86.6 ± 17.7 | 84.8 ± 10.6 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Mean creatinine clearance (mL/min):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan | 186.5 ± 68.2 | 122.2 ± 38.3 | < 0.0001
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril | 156.0 ± 56.6 | 113.1 ± 36.5 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | 13) Proteinuria: Mean albumin excretion (mg/day) in subgroup with microalbuminuria:
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Losartan (n = 8) | 121 (32.0–264.5) | 54.8 (8.6–261.0) | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #4040 | | | | | | | Fosinopril (n = 7) | 154 (44–300) | 14 (10.6–46.0) | < 0.05
Koylan, Acarturk, Canberk, et al., 2005 #860 | Geographical location: Turkey Study dates: May 2000–May 2001 Funding source: NR Interventions: - Irbesartan (n = 337) - ACE inhibitors (n = 298) - CCB (n = 308) Administered “according to approved prescribing guidelines” (details not provided) Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: No, consecutive patients allocated to treatment group in order (max of 6 patients/physician) Baseline/run-in period: None Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: 1053 - Eligible for inclusion: 998 - Randomized: NA - Began treatment: 983 - Completed treatment: 872 - Withdrawals/losses to followup: 118 (25 due to AEs; 8 due to lack of efficacy; 85 failed to return) Age: Mean (SD): 52.7 to 54 Median: NR Range: NR Sex (n [%]): Female: 56.6% Male: 43.4% Race/ethnicity (n [%]): NR Baseline blood pressure: BP measured in morning after 15 min of rest in the supine position Baseline values (± SEM): | | | | | 1) Blood pressure: No quantitative data reported. Investigators reported no significant differences among the three treatments for: - Reduction in supine SBP and DBP values (vs. baseline) at 1, 3, and 6 months - Percentage of patients with normalized SBP and DBP (≤ 140 mmHg and ≤ 90 mmHg, respectively) at 1, 3, and 6 months 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: | | | | | General comments: None Quality assessment: Overall rating: Poor Comments: - Used supine BP - Primary objective was to evaluate compliance, not efficacy Applicability: - Unusual recruitment strategy that seems highly susceptible to selection bias, as reflected by baseline differences in Table 1
Koylan, Acarturk, Canberk, et al., 2005 #860 | | | [underlined: Irbe] | [underlined: ACE] | [underlined: CCB] | | | [underlined: Irbesartan] | [underlined: ACE] | [underlined: CCB]
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Supine SBP | 160.9 ± 16.2 | 159.6 ± 15.2 | 160.7 ± 14.0 | | Any AE | 54 (14.3%) | 76 (25.5%) | 60 (19.5%)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Supine DBP | 96.2 ± 7.4 | 96.5 ± 7.5 | 95.9 ± 7.2 | | P = 0.001 Withdrawals due to AEs: Irbesartan: 0 ACEI: 23/298 (7.7%) CCB: 2/308 (< 1%) 6) Specific adverse events: n (%)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Concurrent medications (n [%]):None Comorbidities (n [%]): | | | | | | [underlined: Irbe] | [underlined: ACE] | [underlined: CCB]
Koylan, Acarturk, Canberk, et al., 2005 #860 | | LVH | 6.6–8.9% | | | | Ankle edema | 3 (<1%) | 5 (1.7%) | 20 (6.5%)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Angina/previous MI | 5.4–6.3% | | | | Constipation | 6 (1.6) | 2 (<1) | 10 (3.2)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Prior cor revasc | 1.4–2.8% | | | | Cough | 3 (<1) | 28 (9.4) | 4 (1.3)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Heart failure | <1–1.8% | | | | Dry mouth | 14 (3.7) | 19 (6.4) | 11 (3.6)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Stroke/TIA | 0–1.1% | | | | Dizziness | 4 (1.1) | 7 (2.3) | 5 (1.6)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Nephropathy | <1–3.6% | | | | Headache | 7 (1.9) | 12 (4.0) | 7 (2.3)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Periph art disease | <1– 2.9% | | | | Nausea | 7 (1.9) | 9 (3.0) | 3 (<1)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Retinopathy | 2.4–2.9% | | | | Feeling sick | 15 (4.0) | 7 (2.3) | 14 (4.5)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | Recruitment setting: Patients recruited by internists or cardiologists at multiple university hospitals Inclusion criteria: - Age > 18 yr - Mild-to-moderate HTN (90 ≤ DBP ≤ 110 mm Hg) - Newly diagnosed with HTN or patients on HTN monotherapy for whom a change in treatment was indicated Exclusion criteria: - Secondary HTN - DBP ≥ 110 mmHg - Currently treated with 2–3 anti-HTN drugs or combo agents - Pregnant or lactating - Neurological or mental disorders - MI or CVA < 6 mo - Severe renal or liver failure | | | | | Pyrosis | 9 (2.4) | 8 (2.7) | 6 (1.9)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | | | | | | Insomnia | 6 (1.6) | 7 (2.3) | 8 (2.6)
Koylan, Acarturk, Canberk, et al., 2005 #860 | | | | | | | 7) Persistence/adherence: A higher proportion of patents receiving irbesartan took their daily dose of medication than ACE or CCB (p = 0.0005) (see Figure 1) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Lacourciere, Belanger, Godin, et al., 2000 #5550 | Geographical location: 8 centers in Canada Study dates: NR Funding source: Merck Interventions: - Losartan 50–100 mg daily (n = 52) - Enalapril 5–20 mg daily (n = 51) Dose titration/co-interventions: - Losartan: Start at 50 mg daily x 8 wks. If DBP > 85, then increase to100 mg daily. If DBP >85 at week 12, then add HCTZ 12.5 mg daily titrated to 25 mg until DBP ≤ 85 (could then add other BP meds to achieve goal, but not specified by protocol) - Enalapril: Start at 5 mg daily x 4 wk. If DBP > 85, then increase to 10 mg daily. At week 8, if DBP still > 85, then increase to 20 mg daily. At week 12, if DBP still > 85, then add HCTZ 12.5 mg daily and titrate to 25 mg until DBP ≤ 85 (could then add other BP meds to achieve goal, but not specified by protocol) Patients with DBP > 100 at week 20 were discontinued from study. Early titration allowed in patients at week 4 if DBP > 105. Study design: RCT- parallel group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in. Was preceded by 7- day wash out of previous HTN meds (14-day wash out of ACEIs) Duration of treatment: 52 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 103 - Began treatment: 102 - Completed treatment: 92 - Withdrawals/losses to followup: 11 Age: Mean: 58.5 Median: NR Range: NR Sex (n [%]): Female: 20 (19.4%) Male: 83 (80.6%) Race/ethnicity (n [%]): Caucasion: 99 (96%) Asian: 3 (3%) Black: 1 (1%) Baseline blood pressure: Trough BP measured using standard mercury sphygmomanometer after 5 min rest; average of 3 measurements: | | | | | 1) Blood pressure: Average of 3 seated trough clinic values (SD): | | | | | General comments: - Small study - No description of recruiting strategy or number of patients screened to generate study sample - Do not present complete data for many outcomes, only those that are statistically significant - 2 patients (1 in each group) excluded from analysis due to uncontrolled hypertension Quality assessment: Overall rating: Fair Comments: See above Applicability: - Placebo run-in limits assessment of discontinuation rates - Missing a great deal of data on the number of analyses performed and specific data; they seem to report selectively the statistically significant findings - Long list of exclusions for patients with CV comorbidities
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | | [underlined: Losartan] | [underlined: Enalapril] | | | | [underlined: SBP] | [underlined: DBP]
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | SBP | 162.3 ± 16.2 | 157.7 ± 15.9 | | | Losartan :
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | DBP | 97.2 ± 6.3 | 95.3 ± 4.8 | | | Pre: | 163.3 ± 16.2 | 97.2 ± 6.3
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | Concurrent medications (n [%]):NR Comorbidities (n [%]): NR (all diabetic) Recruitment setting: NR (seems like outpatient clinics) Inclusion criteria: - DM2 dx at age ≥ 30 - Sitting DBP 90–115 - Urinary albumin excretion 20–350 mcg/min Exclusion criteria: *There was a placebo run-in period. Didn’t indicate how many were excluded by run-in. - Suspicion of renovascular disease - History of malignant htn (SBP>210 mmHg) - Stroke, TIA, or MI in previous 12 months - Significant heart conduction distubances or arrhythmia - Unstable angina - History of heart failure - Serum Cr ≥ 200 mmol/L - Serum potassium ≥ 5.5 mmol/L or ≤ 3.5mmol/L - Treatment with oral corticosteroids - Concomitant use of agents that may affect BP except B-blockers and nitrates - Drug or alcohol abuse - Pregnancy or breast feeding - Ineffective contraception | | | | | Post (52 wk): | 148.3 ± 17.1 | 86.8 ± 9.6
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | | | | | | Enalapril:
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | | | | | | Pre: | 157.7 ± 15.9 | 95.3 ± 4.8
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | | | | | | Post (52 wks): | 145.5 ± 18.2 | 84.4 ± 8.4
Lacourciere, Belanger, Godin, et al., 2000 #5550 | | | | | | | Clinic BP at other time points measured, but not reported. Also report 24-h ambulatory BP at 4 time points during study (baseline, week 12, 28, and 52) – but only 5 of 8 sites did this. 2) Rate of use of a single antihypertensive agent for BP control: Losartan group on monotherapy – 20/52 (38.5%) Enalapril group on monotherapy – 31/52 (59.6%) 3) Mortality: No deaths 4) Morbidity: No CV events 5) Safety: Withdrawals due to AEs: Enalapril – 1 (cough) Losartan – 2 (1 w/ dyspnea and 1 w/ urticaria) 6) Specific adverse events: Cough: Enalapril – 7 patients (14%) Losartan - 0 patients 7) Persistence/adherence: NR 8) Lipid levels: Total cholesterol difference at 52 wk compared to baseline (pre-/post- values NR): Losartan: 2.1% decrease Enalapril: 4.2% decrease P < 0.05 Also report limited data on LDL for losartan only and triglycerides for enalapril only. 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: HbA1c change at 52 wks compared to baseline (pre-/post- values NR): Losartan: + 0.006 Enalapril: + 0.0025 11) LV mass/function: NR 12) Creatinine/GFR: GFR declined approx 9% in each group by week 52 (P < 0.001 for pre-/post- analysis). Values not given for GFR at 52 wk. 13) Proteinuria: Urine albumin excretion based on average of 3 measurements: Losartan: Pre: 64.1 mcg/min (no SD given) Post (52 wk): 41.5mcg/min Enalapril: Pre: 73.9mcg/min Post (52 wk): 33.5 mcg/min P-value for pre-post was < 0.001 for both. No significant difference between treatments (no p-value given).
Lacourciere, Neutel, Davidai, et al., 2006 #100 | Geographical location: 81 U.S. and Canadian sites Study dates: Oct 1, 2002 to July 17, 2003 Funding source: NR Interventions: Forced titration of: - Ramipril 2.5, 5, and 10 mg (n = 407) - Telmisartan 40 and 80 mg (n = 405) Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes Was allocation concealment adequate? NR Baseline/run-in period: Screening 1–7 days, placebo run-in phase 2–4 wk Duration of treatment: 14 wk Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: 1998 - Eligible for inclusion: - Randomized: 812 - Began treatment: 812 - Completed treatment: 722 - Withdrawals/losses to followup: 90, 35 due to AEs, 12 due to lack of efficacy, 13 lost to followup, 14 “investigator decision”, 18 patient decision (note: reported numbers do not total correctly) Age: Mean (SD): 52.5 ± 9.8 Median: NR Range: NR Sex (n [%]): Female: 269 (33.1%) Male: 543 (66.9%) Race/ethnicity (n [%]): 87.7% white (712) Baseline blood pressure: Seated trough BP measured by manual cuff sphygmomanometer: | | | | | 1) Blood pressure: Seated trough BP at 14 wk: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Patients and providers not blinded Applicability: - Significant number of limitations to inclusion in the study as evidence by number of screened patients to enrolled
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | [underlined: Telmisartan] | [underlined: Ramipril] | | | | [underlined: Telmisartan] | [underlined: Ramipril] | [underlined: p-value]
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | SPB | 153.9 ± 12.2 | 152.5 ± 12.8 | | | SBP | 139.6 | 143.4 | < 0.0000
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | DBP | 99.7 ± 4.2 | 99.8 ± 4.3 | | | DBP | 88.7 | 92.0 | < 0.0001
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Clinic setting Inclusion criteria: - Age ≥ 18 yr - Mild-moderate hypertension at baseline (mean DBP ≥ 95 and ≤ 109 mm Hg measured by manual cuff and 24-hr DBP > 85 mm Hg measured by ABPM [Spacelabs 90207] during the morning, daytime, and nighttime periods Exclusion criteria: - Mean seated SBP ≥ 180 or mean seated DBP ≥ 110 mm Hg during any visit of the placebo run-in or if they had secondary hypertension, CHF, stroke within 6 months, PTCA within 3 months, hemodynamically significant valvular heart disease, myocardial obstructive pathologic conditions, or clinical relevant arrhythmias - Night shift workers excluded - Excluded for relevant organ system disease (poorly controlled diabetes, significant hepatic, renal dysfunction, - Any hypersensitivity or reaction (including angioedema) to ACEI or ARB, history of non-compliance, substance abuse, sodium depletion, hypokalemia, or hyperkalemia, hereditary fructose intolerance, bililary tract obstruction | | | | | SBP response at 14 wk (trough seated SBP < 140 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 70.7% Ramipril: 62.7% p < 0.01 DBP response at 14 wk (trough seated DBP < 90 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 60.5% Ramipril: 46.8% p < 0.01 ABPM outcomes also reported (primary) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Severe AEs: Telmisartan: 15 (3. 8%) Ramipril: 30 (7.4%) Serious AEs: 14 patients (treatment group NR), none considered to be drug-related Withdrawals due to AEs: Telmisartan: 12 (3.0%) Ramipril: 23 (5.7%) 6) Specific adverse events: AEs occurring at a rate of ≥ 1% and judged to be drug-related:
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | | [underlined: Telmisartan] | [underlined: Ramipril]
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | Peripheral edema | 4 (1%) | 0
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | Dizziness | 6 (1.5%) | 4 (1%)
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | HA | 4 (1%) | 6 (1.5%)
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | Cough | 1 (0.2%) | 33 (8%)
Lacourciere, Neutel, Davidai, et al., 2006 #100 | | | | | | | 7) Persistence/adherence: Monitored via an unspecified process but NR. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Larochelle, Flack, Marbury, et al., 1997 #6790 | Geographical location: NR; investigators from Canada, Brazil, S. Africa, US Study dates: NR Funding source: Bristol-Myers Squibb Interventions: - Irbesartan (n = 121) 150 mg once daily - Enalapril (n = 61) 20 mg once daily At end of 1 week if seated DBP was ≥ 90, then titration of irbesartan to 300 mg, enalapril to 40 mg After week 4, if seated DBP was ≥ 90, open-label once-daily adjunctive antihypertensive medications were added (HCTZ 25–50 mg/day, followed by long-acting nifedipine 30–60 mg.day and/or atenelol 50–100 mg/day) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: Diuretics withdrawn for at least 3 days, other anti-hypertensives for at least 24 hr. Patients with seated DBP > 115–130 entered to double-blind phase Those with DBP ≤ 115 entered a single-blind placebo lead-in period of up to 7 days Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 182 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: 72 (40%) Male: 110 (60%) Race/ethnicity (n [%]): White: 98 (54%) Black: 58 (32%) Other: 26 (14%) Baseline blood pressure: Trough-seated DBP 24 ± 3 hr after ingestion of previous day’s medication | | | | | 1) Blood pressure: Reduction in trough seated DBP from baseline at 12 wk: Percentage of patients “normalized” (trough seated DBP < 90 mm Hg) at 12 wk: Irbesartan: 59% Enalapril: 57% p = 0.97 Percentage of “responders” (trough seated DBP normalized or reduced ≥ 10 mm Hg from baseline) at 12 wk: Irbesartan: 100% Enalapril: 98% p = 0.97 2) Rate of use of a single antihypertensive agent for BP control (%): On monotherapy at 12 wk: Irbesartan: 9% Enalapril: 7% Also taking HCTZ: Irbesartan: 24% Enalapril: 18% Taking ≥ 3 adjunctive meds: Irbesartan: 67% Enalapril: 75% 3) Mortality: NR 4) Morbidity: NR 5) Safety: No changes in lab parameters, ECG findings or physical exam findings Patients with AEs (%): Irbesartan: 55% Enalapril: 64% 6) Specific adverse events (%): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Setting of study; no description (country? system? center selection? study clinicians?) - No data regarding numbers of patients screened or eligible for inclusion - Raw numbers not reported, only percentages Applicability: - Patient compliance not assessed
Larochelle, Flack, Marbury, et al., 1997 #6790 | | | [underlined: Irbesartan] | [underlined: Enalapril] | | | | [underlined: Irbesartan] | [underlined: Enalapril]
Larochelle, Flack, Marbury, et al., 1997 #6790 | | SBP | 176.7 ± 17.8 | 175.4 ± 15.2 | | | Headache | 17.4% | 19.7%
Larochelle, Flack, Marbury, et al., 1997 #6790 | | DBP | 119.2 ± 3.9 | 119.0 + 3.3 | | | Dizziness | 9.1% | 18.0%
Larochelle, Flack, Marbury, et al., 1997 #6790 | | Concurrent medications (n [%]): NR (though see Exclusion criteria) Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR Inclusion criteria: - Seated diastolic BP 115–130 - Men and surgically sterile or post-menopausal women > 18 yr - Signed an informed consent Exclusion criteria: - Concomitant disease that would present safety hazards - Concomitant medications known to affect BP - Patients with seated BP < 115 at day 7 of wash-out period | | | | | Cough | 2.5% | 13.1%*
Larochelle, Flack, Marbury, et al., 1997 #6790 | | | | | | | URI | 9.9% | 13.1%
Larochelle, Flack, Marbury, et al., 1997 #6790 | | | | | | | *p= 0.007 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Mackay, Pearce, and Mann, 1999 #12650 | Geographical location: United Kingdom Study dates: Immediate post-marketing period for 4 drugs, through 6 mo followup Enalapril (1985) Lisinopril (1988) Perindopril (1990) Losartan (1995) Funding source: Pharmaceutical companies Interventions: - Enalapril (dose NR; n = 15,361 analyzed) - Lisinopril (dose NR; n = 12,438 analyzed) - Perindopril (dose NR; n = 9089 analyzed) - Losartan (dose NR; n = 14,522 analyzed) Study design: Prospective cohort Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate : NA Baseline/run-in period: NA Duration of treatment: Up to 6 mo Duration of post-treatment followup: Up to 6 mo | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: NA - Began treatment: NR - Completed treatment: 51,410 analyzed - Withdrawals/losses to followup: NR (except for withdrawals due to cough) Age: Mean (SD): 61.9 (~ 13) Median: NR Range: NR Sex (n [%]): Female: 28,215 (55.7%) Male: 22,478 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): Cardiac failure 8.8% Recruitment setting: Initial post-marketing surveillance cohort Inclusion criteria: All patients dispensed incident prescriptions for each drug in the immediate post-marketing period in England; and their prescribing general practitioners were mailed a questionnaire Exclusion criteria: NR, but presumably failure of GP to return questionnaire | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: Patients with cough: | | | | | General comments: - Authors suggest most cough associated with losartan is due to carry over from ACEI, since most patients put on losartan were switched for ACEI-related cough Quality assessment: Overall rating: Poor Comments: - Non-concurrent time periods for assessment of different drugs - Assembly of cohort not well-described Applicability: - Assessment in first few months of use of new drug products suggests that prescribing patterns may no longer be the same
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Drug | Pts w/cough | Rate per 1000 pt-mo | 95% CI
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Enalapril | 86 | 3.9 | 3.1 to 4.8
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Lisinopril | 270 | 14 | 13 to 16
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Perindopril | 210 | 16 | 14 to 19
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Losartan | 64 | 3.1 | 2.4 to 4.0
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Rate ratios for cough, day 8 to 60, compared to losartan:
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Drug | RR crude | RR adj for age and sex | 95% CI
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Enalapril | 1.3 | 1.5 | 1.2 to 2.2
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Lisinopril | 4.6 | 4.8 | 3.6 to 6.5
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Perindopril | 5.3 | 5.7 | 4.2 to 7.6
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Rate ratios for cough; females compared with males
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Drug | RR crude | RR adj for age | 95% CI
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Enalapril | 1.5 | 1.4 | 0.8 to 2.5
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Lisinopril | 1.6 | 1.6 | 1.2 to 2.2
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Perindopril | 1.6 | 1.6 | 1.2 to 2.1
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | Losartan | 1.7 | 1.5 | 0.8 to 2.6
Mackay, Pearce, and Mann, 1999 #12650 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Malacco, Santona-staso, Vari, et al., 2004 #2130 | Geographical location: 88 outpatient centers in Italy Study dates: NR Funding source: Novartis Interventions: - Valsartan 160 mg (n = 604) - Lisiniopril 20 mg (n = 609) Dose titration and co-interventions: No dose titration; HCTZ 12.5 mg added at 4 wk for non-responders (SBP > 150 or decrease < 20 [if SBP < 180] or decrease < 30 [if SBP ≥ 180]) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: NR - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 16 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 1213 - Began treatment: 1213 - Completed treatment: 1100 - Withdrawals/losses to followup: 113 (32 due to AEs, other causes NR) Age: Mean (SD): 54.1 (10.1) Median: NR Range: 28–78 Sex (n [%]): Female: 578 (48%) Male: 635 (52%) Race/ethnicity (n [%]): White: 100% Baseline blood pressure: Trough seated BP measured 3 times after 5-min rest using mercury sphygmomanometer; mean of 3 readings used Mean baseline values ( ± SD): | | | | | 1) Blood pressure: Mean BP (± SD) at 16 wk (ITT population): | | | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | Valsartan (n = 594) | Lisinopril (n = 591) | | | | Valsartan (n = 594) | Lisinopril (n = 591) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | SBP | 167.4 ± 10.2 | 167.2 ± 9.5 | | | SBP | 137.2 ± 13.3 | 136.8 ± 12.2 | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | DBP | 99.3 ± 4.2 | 99.1 ± 4.3 | | | DBP | 83.9 ± 7.1 | 83.7 ± 7.0 | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age ≥ 18 yrs - Mild to severe HTN (SBP 160–220 and DBP 95–110) Exclusion criteria: - Malignant HTN - TIA, CVA, or MI within 6 months - Secondary HTN - CHF - Clinically relevant arrhythmia - Clinically significant valvular heart disease - Liver disease - Hyperkalemia - Serum creatinine > 1.5 times normal - Type 1 diabetes - Type 2 diabetes with poor glucose control or neuropathy - Known hypersensitivity to ARB, ACEI, or thiazides - Pregnant, possibly pregnant, or breastfeeding women - Women of childbearing age not using birth control | | | | | Rates of BP control (SBP ≤ 150 or decrease ≥ 20 [if baseline SBP < 180] or ≥ 30 [if baseline SBP ≥ 180]): Valsartan: 428 (82.6%) Lisinopril: 409 (81.6%) p = NS Also reported: Mean BP at 16 wk for per-protocol population Mean reductions in BP vs. baseline (ITT and per-protocol populations) 2) Rate of use of a single antihypertensive agent for BP control: Valsartan: 79.3% Lisinopril: 78.7% 3) Mortality: No deaths occurred during trial 4) Morbidity: NR 5) Safety: Any drug-related AE: Valsartan: 31/604 (5.1%) Lisinopril: 65/609 (10.7%) p = 0.001 Severe AEs: Valsartan: 3/604 (< 0.5%) Lisinopril: 3/609 (< 0.5%) Withdrawals due to AEs: Valsartan: 9/604 (1.5%) Lisinopril: 23/609 (3.8%) p = 0.01 6) Specific adverse events: Drug-related AEs: | | | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | | Valsartan (n = 604) | Lisinopril (n = 609) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Cough* | 6 (1%) | 44 (7.2%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Headache | 4 (0.7%) | 9 (1.5%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Vertigo | 4 (0.7%) | 1 (0.2%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Asthenia | 3 (0.5%) | 4 (0.7%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Palpitations | 2 (0.3%) | 2 (0.3%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | Hypotension | 1 (0.2%) | 3 (0.5%) | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Malacco, Santona-staso, Vari, et al., 2004 #2130 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | General comments: None Quality assessment: Overall rating: Good Applicability: - Setting/recruitment/selection NR - Exclusion criteria strict and vague
Mallion, Bradstreet, Makris, et al., 1995 #12090 | Geographical location: Multicenter, with sites in Italy, Costa Rica, France, Switzerland, New Zealand, Germany, Austria, The Netherlands, and Portugal Study dates: NR Funding source: NR (multiple authors from Merck) Interventions: - Losartan 50–100 mg (n = 109) - Captopril 50–100 mg (n = 54) Dose titration and co-interventions: Patients started on 50 mg and titrated up to 100 mg if BP not controlled (DBP 90–115 mm Hg) at 6 wk; no co-interventions allowed Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes – details not specified Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: 1 wk without study drugs to determine rebound HTN | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 163 - Began treatment: 163 - Completed treatment: 142 - Withdrawals/losses to followup: 21 (15 due to AEs, 3 lost to followup, 3 not described) Age: Mean (SD): 54.1 Median: NR Range: NR Sex (n [%]): Female: 63 (39%) Male: 100 (61%) Race/ethnicity (n [%]): Caucasian: 145 (89%) Oriental: 2 (1%) Latin American: 9 (6%) Black: 4 (2%) Asian: 3 (2%) Baseline blood pressure: Trough seated BP measured 3 times at 1-min intervals after 5 min rest (instrument not specified); average of 3 readings used | | | | | 1) Blood pressure: Mean BP at 12 wk: | | | | | General comments: - Patients withdrawn if DBP not ≥ 95 during placebo run-in period resulting in some potential exclusions - Primary outcome was change in DBP, but one wonders if this was established a priori since it was the only significant BP change during the study. - Randomization stratified by degree of hypertension (mild vs. moderate) Quality assessment: Overall rating: Fair Comments: - Numbers of screened and eligible patients NR Applicability: - Minimal racial diversity (89% Caucasian) - Recruitment setting(s) not described - Minimal comorbidities in study population of hypertensive patients
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | [underlined: Losartan] | [underlined: Captopril] | | | | Losartan (n = 109) | Captopril (n = 51)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | SBP | 159.3 (16.8) | 159.4 (16.2) | | | SBP | 149.8 (20.3) | 151.4 (16.4)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | DBP | 103.1 (5.3) | 103.7 (5.5) | | | DBP | 93.9 (9.3) | 97.9 (9.2)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | Concurrent medications (n [%]): - Non-study BP meds not permitted - Allowed acetaminophen, aspirin, NSAIDs Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Age ≥ 18 yr - Mild-to-moderate essential HTN (mean sitting DBP 90–115 before placebo run-in, then 95–115 after 2 and 4 wk on placebo) Exclusion criteria: - Known hypersensitivity/contraindication (including angioedema, cough) to captopril or other ACEI - Significant cardiovascular, cerebrovascular, renal/hepatic disease - Secondary or malignant HTN - Recent MI - Serum K <3.5 or > 5.5 mmol/L or other laboratory values outside of the normal ranges - Women of child-bearing age if not surgically sterile or using effective contraception | | | | | Adjusted* mean change in BP at 12 wk:
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | | Losartan (n = 109) | Captopril (n = 51) | P-value
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | SBP | −9.1 | −7.9 | NS
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | DBP | −9.1 | −5.7 | ≤ 0.01
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | *Adjusted for baseline BP BP response rates at 12 wk (DBP < 90 or DBP ≥ 90 with reduction of ≥ 10 from baseline): Losartan: 55/109 (50.5%) Captopril: 15/51 (29%) p ≤ 0.05 Subgroup analyses (no formal statistical testing done): Mean reduction in DBP at 12 wk, age < 65 vs. ≥ 65:
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | | [underlined: Age < 65] | [underlined: Age ≥ 65]
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Losartan DBP | −9.4 | −8.1
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Captopril DBP | −5.1 | −7.7
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Sex “not a significant demographic factor, although DBP reductions were slightly higher in men at all time-points within both treatment groups” 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensive meds allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | | Losartan (n [%]) | Captopril (n [%])
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | ≥ 1 AE Withdrawals | 42 (38.5%) | 20 (37.0%)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | due to AEs | 10 (9.2%) | 5 (9.3%)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Drug-related AEs | 16 (14.7%) | 10 (18.5%)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | 6) Specific adverse events: AEs occurring in > 4% of patients in either group:
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | | Losartan (n = 109) | | Captopril (n = 54)
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | | n (%) | DR | n (%) | DR
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Headache | 8 (7.3) | 2 | 4 (7.4) | 3
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Nausea | 6 (5.5) | 1 | 2 (3.7) | 2
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | Dizziness | 4 (3.7) | 1 | 3 (5.6) | 2
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | URI | 5 (4.6) | 0 | 0
Mallion, Bradstreet, Makris, et al., 1995 #12090 | | | | | | | DR = # AEs considered to be drug-related 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Malmqvist, Kahan, and Dahl, 2000 #5650 | Geographical location: 56 centers, locations not reported Study dates: NR Funding source: Astra Hässle AB Interventions: - Candesartan 8 to 16 mg (n = 140) - Enalapril 10 to 20 mg (n = 146) - HCTZ 12.5 to 25 mg (n = 143) Dose titration/co-interventions: Higher doses used if DBP > 90 mm Hg after 6 wk; no co-interventions Study design: RCT, parallel-group Blinding: - Patients: Yes (double-dummy) - Providers: NR - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 6-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 512 - Randomized: 429 - Began treatment: 429 - Completed treatment: 404 - Withdrawals/losses to followup: 26 (17 due to AEs, 9 for other reasons) Age: Mean: 57.7 Median: Range: 40 to 70 Sex (n [%]): Female: 100% Male: 0% Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured in duplicate, with an interval of at least 1 min, after patient rested in seated position for 5 min Mean baseline values NR Concurrent medications (n [%]): Non-study medication that would affect BP not allowed; no changes permitted to hormone replacement therapy Comorbidities (n [%]): History of habitual smoking: 9% Estrogen replacement: 22% Recruitment setting: NR Inclusion criteria: - Women age 40–69 yr - Untreated or treated primary hypertension (seated DBP 95–115) from a mean of 2 measurements at the end of placebo run-in period Exclusion criteria: - Secondary or malignant hypertension - Seated SBP > 200 mm Hg - MI, stroke, coronary bypass surgery, TIA within prior 6 mo - Angina, aortic/mitral valve stenosis, heart failure, or arrhythmia - Insulin-treated diabetes - Gout - Severe concomitant disease that may interfere with assessment - Any condition associated with poor compliance (e.g., drug or alcohol abuse) | | | | | 1) Blood pressure: Mean post-treatment BP values NR Mean change in seated trough BP from baseline to 12 wk (no variance data reported): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Mean baseline and post-treatment BP values NR - Patients withdrawn from study if mean seated SBP > 200 mm Hg or DBP > 110 mm Hg on > 2 occasions in 1 wk Applicability: - High loss during placebo run-in period (62/512 initially enrolled) - 100% women - Exclusion of patients who did not respond to therapy (seated SBP > 200 mm Hg or DBP > 110 mm Hg on > 2 occasions in 1 wk) means that analyzed population is a selected group of those who did respond; leads to bias
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | | [underlined: Candesartan] | [underlined: Enalapril]
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | SBP | −19 | −13
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | DBP | −11 | −9
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Mean difference between treatments (candesartan vs. enalapril) in change in seated trough BP from baseline to 12 weeks:
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | | [underlined: Mean diff] | [underlined: 95% CI] | [underlined: P-value]
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | SBP | −5.5 | −9.1 to −1.9 | < 0.01
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | DBP | −2.2 | −3.9 to −0.5 | = 0.01
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | BP control rates (seated DBP ≤ 90 mm Hg) at 12 wk: Candesartan: 60% Enalapril: 51% p = NS 2) Rate of use of a single antihypertensive agent for BP control: No other antihypertensives permitted 3) Mortality: NR 4) Morbidity: No difference in Psychological General Well-Being, McMaster Overall Treatment Evaluation Questionnaire (data not reported) 5) Safety: Any AEs: Candesartan: 60% Enalapril: 67% 10 serious AEs were reported (treatment groups not specified); none assessed as related to study drug 17/429 randomized patients (4%) withdrew due to AEs; treatment groups not specified 6) Specific adverse events: Number of patients (%):
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | | [underlined: Candesartan] | [underlined: Enalapril]
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Respiratory infection | 12 (8) | 7 (5)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Fatigue | 11 (8) | 7 (5)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Headache | 10 (7) | 27 (19)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Dizziness | 6 (4) | 10 (7)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Cough | 0 (0) | 19 (13)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | Palpitations | 5 (4) | 0 (0)
Malmqvist, Kahan, and Dahl, 2000 #5650 | | | | | | | 7) Persistence/adherence: Compliance (defined as amount of prescribed medication taken) was between 75 and 125% in all but 2 patients; not reported by treatment group 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Marentette, Gerth, Billings, et al., 2002 #12830 | Geographical location: Saskatchewan, Canada (database including > 90% of provincial residents) Study dates: Jan 1994-Dec 1998 Funding source: Merck Frosst Canada, Ltd. Interventions: Number of patients with data for at least 180 days: ARBs (n = 267) ACEIs (n = 7466) Beta-blockers (n = 4295) CCBs (n = 3200) Diuretics (n = 9623) Alpha-blockers (n = 731) Alpha-agonists (n = 575) Vasodilators (n = 25) Mixed classes (more than 1 class concurrently or sequentially during study period; n = 20,276) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Patients followed for minimum of 180 days to a maximum of 720 days | Number of patients: - Screened for inclusion: 51,029 - Eligible for inclusion: 46,458 - Randomized: NA - Began treatment: NA - Completed treatment: NA - Withdrawals/losses to followup: NA Age (ARBs and ACEIs): Mean: 58 Median: NR Range: 1–85 Sex (ARBs and ACEIs; %): Female: 48.8% Male: 51.2% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]):NR Comorbidities (n [%]):NR Recruitment setting: Population-based prescription drug database Inclusion criteria: - ICD-9 code diagnosis of hypertension (401, 402, 403, 404, or 4-digit codes included in these categories) - At least 1 antihypertensive prescription during first 4.5 yr of study period - No antihypertensive prescription in the 12 mo before the first prescription Exclusion criteria: None specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Sample sizes at various timepoints: | | | | | General comments: - Relatively small number of patients in ARB subgroup Quality assessment: Overall rating: Fair Comments: - Non-random allocation to drugs - No data on comparability of patients on ACEIs versus ARBs - Funded by pharmaceutical company Applicability: - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | | [underlined: ARBs] | [underlined: ACEIs]
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 180 days | 267 | 7466
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 360 days | 170 | 6539
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 540 days | 44 | 5699
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 720 days | 3 | 4826
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | Small ARB sample explained by fact that ARBs not listed in provincial formulary until March 1996. Patient classified as persistent at a given period of observation (180, 360, 540, or 720 days) if patient filled at least one prescription within 90 days of the end of the given period and within 90 days of the end of each prior interval. Extrapolating from Figure 2, persistence was:
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | | [underlined: ARBs] | [underlined: ACEIs]
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 180 days | 87% | 75%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 360 days | 85% | 65%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 540 days | - | 60%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 720 days | - | 55%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | When considering all drug classes, persistence was higher for males and for older ages. Persistence was reported by age for ACEIs (but not ARBs):
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 1–47 yr: | 71.7%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 48–57: | 76.1%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 58–66: | 74.5%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 67–74: | 76.5%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | 75–95: | 77.0%
Marentette, Gerth, Billings, et al., 2002 #12830 | | | | | | | Note: “Persistence” includes combinations and switches; in essence, what is being modeled is failure to discontinue. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Matsuda, Hayashi, and Saruta, 2003 #12110 | Geographical location: Honjo, Ashikaga, Tochigi, Japan Study dates: 1998–1999 Funding source: NR Interventions: - ACE group - perindopril 2 mg or trandolapril 1 mg (dose titrated to achieve SBP < 135 and DBP < 85) (n = 27) - ARB group – losartan 25 mg or candesartan 4 mg (dose titrated to achieve SBP < 135 and DBP < 85) (n = 25) Study design: RCT, parallel-group Blinding: - Patients: NR - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: NR Duration of treatment: 48 weeks Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 52 - Began treatment: 52 - Completed treatment: 52 - Withdrawals/losses to followup: 0 Age: Mean (SD): 52 Median: NR Range: NR Sex (n [%]): Female: 23 (44%) Male: 29 (56%) Race/ethnicity (n [%]): NR Baseline blood pressure: Average of 2 measurements taken after 5 min in sedentary position (seated or supine NR) | | | | | 1) Blood pressure: | | | | | General comments: - All data were presented to compare subgroups with mild and moderate proteinuria with regard to effect of ACEI versus ARB Quality assessment: Overall rating: Poor Comments: - Poorly described methods regarding washout, co-interventions, dose titration - Position of BP measurement not described - No data on safety/adverse events Applicability: - Patient ethnicity not described, but likely all Japanese
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | Mild proteinuria | | Mod proteinuria | | | Mild proteinuria | | Mod proteinuria
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | ACE | ARB | ACE | ARB | SBP | ACE | ARB | ACE | ARB
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | n = 13 | n = 13 | n = 14 | n = 12 | Baseline | 148±3 | 154±4 | 152±4 | 150±3
Matsuda, Hayashi, and Saruta, 2003 #12110 | | S | 148 ± 3 | 154 ± 4 | 152 ± 4 | 150 ±3 | 12 wk | 135±3 | 137±3 | 134±4 | 137±4
Matsuda, Hayashi, and Saruta, 2003 #12110 | | D | 86 ± 5 | 86 ± 3 | 90 ± 3 | 89 ± 3 | 24 wk | 132±4 | NR | 120±3 | NR
Matsuda, Hayashi, and Saruta, 2003 #12110 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinic Inclusion criteria: - Hypertension (SBP > 140 and/or DBP > 90 mmHg) - Proteinuria (> 0.3 g/24 hr) - Serum creatinine level < 265 μmol/L or creatinine clearance > 30 mL/min/1.72 m^2^ Exclusion criteria: - Diabetic nephropathy - Polycystic kidney disease - Chronic pyelonephritis | | | | | 48 wk | 131±4 | NR | 124±3 | NR
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | | Mild proteinuria | | Mod proteinuria
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | DBP | ACE | ARB | ACE | ARB
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | Baseline | 86±5 | 86±3 | 90±3 | 89±3
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | 12 wk | 76±4 | 71±2 | 78±3 | 79±3
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | 24 wk | 80±3 | NR | NR | NR
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | 48 wk | 74±4 | NR | NR | NR
Matsuda, Hayashi, and Saruta, 2003 #12110 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: “Neither ACE-I nor ARB had any effect on creatinine clearance” 13) Proteinuria: No change in patients with mild proteinuria. In patients with moderate proteinuria, ACEI reduced proteinuria by 44 ± 6% (from 2.7 ± 0.5 to 1.5 ± 0.4 g/d; p < 0.05, n = 14) at 12 wks and 54 ± 7% at 48 wk (1.2 ± 0.2 g/d) ARB caused a 23 ± 8% decrease (from 2.7 ± 0.4 to 2.0 ± 0.4 g/d, p > 0.2, n = 12) at 12 wk (p < 0.05 versus ACEI) and 41% at 48 wk (p > 0.5 versus ACEI)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | Geographical location: Italy Study dates: 2000-2001 Funding source: Pfizer Italia Interventions: A single antihypertensive in one of the following classes: - α-blockers (n = 662) - Diuretics (n = 2177) - β-blockers (n = 1780) - Calcium channel blockers (CCBs, n = 2700) - ACE inhibitors (n = 4602) - ARBs (n = 1382) Study design: Retrospective cohort study Blinding: NA Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 365 days Duration of post-treatment followup: NA | Number of patients: Of 409,724 in the Health Search Database, 24,540 were newly diagnosed with hypertension; of these, 13,303 satisfied inclusion criteria (4967 did not receive antihypertensive therapy within 90 days of diagnosis, 6270 were started on combination therapy) Age (ACEI/ARB): Mean (SD): 66.0 (12.8)/64.0 (12.6) Median: NR Range: NR Sex (ACEI/ARB; n [%]): Female: 2484 (54.0%)/770 (55.7%) Male: 2118 (46.0%)/612 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: Average of last 2 separate measurements made by physicians within 3 mo before index date; method of assessment not specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: See below, under Persistence/adherence 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Patients classified into one of the following groups: [underlined: Continuers:] Patients continuing the first-line medication for at least 1 yr; [underlined: Combiners:] Patients receiving an additional type of antihypertensive drug and continuing the initial medication; [underlined: Switchers:] Patients changing from the first-line to another antihypertensive class and discontinuing the initial treatment; [underlined: Discontinuers:] Patients stopping the first-line therapy without having another antihypertensive prescription during followup. | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Cohort study, requiring multivariate adjustment to make groups more comparable Applicability: - Reflects Italian practice patterns and study population
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | | [underlined: ACEI] | [underlined: ARB] | | | | ACEI | ARB
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | SBP | 153.1 ± 19.1 | 153.2 ± 18.6 | | | Continuers | 23.3% | 25.2%
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | DBP | 90.1 ± 10.6 | 90.6 ± 10.2 | | | Combiners | 26%* | 25%*
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): | | | | | Switchers | 10%* | 8%*
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | | [underlined: ACE] | [underlined: ARB] | | | Discontinuers | 40%* | 42*
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | CAD | 179 (3.9) | 54 (4.0) | | | * Estimates based on Figure 1; values not reported in text or tables Adjusted hazard ratio for discontinuation = 0.5 (95% CI 0.47 to 0.54) for ACEI, and 0.44 (0.41 to 0.48) for ARB. Adjusted hazard ratio for combining = 1.45 (1.29 to 1.64) for ACEI, and 1.35 (1.16 to 1.57) for ARB (Adjustment included age, sex, baseline BP, comorbidities, and family history) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR.
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | HF | 45 (0.98) | 14 (1.01)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | DM | 564 (12.3) | 101 (7.3)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | Stroke | 141 (3.1) | 43 (3.1)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | Dyslip | 415 (9.0) | 220 (8.7)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | COPD | 244 (5.3) | 85 (6.2)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | Prostate | 218 (4.7) | 53 (3.8)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | 2+ comorbidities | 479 (10.4) | 129 (9.3)
Mazzaglia, Mantovani, Sturkenboom, et al., 2005 #390 | | Recruitment setting: Primary care clinics engaged in the Health Search Database Inclusion criteria: - Newly diagnosed hypertensives (ICD-9: 401-404, 437.2) - Age ≥ 35 yr during 2000-1 - Registered with one of the participating GPs for at least 1 yr before entry into the study - Received at least one antihypertensive medication within 3 mo of diagnosis Exclusion criteria: - Received antihypertensive drugs within 6 months prior to index date - Less than 365 days of valid follow-up after entry to the cohort - Received one-pill combination therapy or multiple pill medications as first-line therapy
McInnes, O’Kane, Istad, et al., 2000 #5680 | Geographical location: Multicenter: Glasgow, UK; Oslo, Norway; Oula, Finland; Oude Wetering, The Netherlands Study dates: NR Funding source: Astra Hassle Interventions: - Candesartan cilexetil 8 mg + HCTZ 12.5 mg (n = 237) - Lisinopril 10 mg + HCTZ 12.5 mg (n = 116) No dose titration; no co-interventions Study design: RCT, parallel-group Blinding: - Patients: Yes (double-dummy) - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes (although blocks of 3 were used, central randomization should have controlled for this) Baseline/run-in period: NR Duration of treatment: 26–30 wk; outcomes reported at 26 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 418 - Randomized: 355 - Began treatment: 353 - Completed treatment: 286 - Withdrawals/losses to followup: 67 Age: Mean (SD): 57.5 ± 9.7 Median: NR Range: NR Sex (n [%]): Female: 158 (45%) Male: 195 (55%) Race/ethnicity (n [%]): Caucasian: 348 (99%) Baseline blood pressure: Seated trough BP assessed using a fully automated device (Omron HEM- 705CP). Mean of 3 measurements taken at 2-min intervals after patient seated for 5 min. | | | | | 1) Blood pressure: Results for ITT population (n = 237 candesartan, 116 lisinopril) Seated BP at 26 weeks: | | | | | General comments: - Patients withdrawn if mean sitting BP > 180/100 at 2 visits 2-4 weeks apart, resulting in high level of withdrawal prior to 26-wk endpoint Quality assessment: Overall rating: Fair Comments: - Not clear if there was a run-in period (mentioned in results, but not methods) - Because no clear run-in, comparison change observed is unclear; would have been better to have placebo run-in to get baseline BP or at least to group results by prior drug type - Difficult to tell how many patients withdrew and the reasons for withdrawal - Very little baseline information about the patients Applicability: - Racially homogenous – all white northern European patients - Recruitment setting not described - Low dose of lisinopril used
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | Candesartan/ HCTZ | Lisinopril/ HCTZ | | | | Candesartan/ HCTZ | Lisinopril/ HCTZ
McInnes, O’Kane, Istad, et al., 2000 #5680 | | SBP: | 169.2 ± 17.2 | 163.3 ± 16.9 | | | SBP | 151.1± 19.1 | 145.9 ± 18.4
McInnes, O’Kane, Istad, et al., 2000 #5680 | | DBP: | 102.9 ± 5.5 | 101.8 ± 4.9 | | | DBP | 93.0 ± 9.3 | 91.2 ± 8.4
McInnes, O’Kane, Istad, et al., 2000 #5680 | | Concurrent medications (n [%]): No other antihypertensives allowed Comorbidities (n [%]): NR (patients reported to be similar across groups in race, height, BMI, medical history, duration of hypertension, and WHO stage.) Recruitment setting: NR Inclusion criteria: - Age 20–80 yr - Primary HTN - Diastolic BP 95–115 on 2 occasions 1-2 wk apart, 24 hr after antihypertensive monotherapy Exclusion criteria: - Women of child-bearing potential - Recent significant CV event or condition - Concomitant drugs with BP modulating effects -Contraindications to any of study drugs -Severe concomitant disease -Conditions associated with poor compliance | | | | | Direct statistical testing NR; analyses of adjusted mean change results have p-values > 0.05. Response rates at 26 wk (seated DBP ≤ 90 mm Hg and/or reduction of ≥ 10 mm Hg from baseline): Candesartan/HCTZ: 129/237 (54.4%) Lisinopril/HCTZ: 72/116 (62.1%) p = 0.094 Other outcomes reported: BP control rates (seated DBP ≤ 90 mm Hg) Mean seated BP at 2 and 12 wk (Figure 1) Standing BP outcomes Some outcomes also reported for per-protocol population 2) Rate of use of a single antihypertensive agent for BP control: Study drugs both combination agents; no other antihypertensives medications allowed 3) Mortality: NR 4) Morbidity: NR 5) Safety:
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | | [underlined: Candesartan] | [underlined: Lisinopril]
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Pts with AEs | 164 (68.9%) | 93 (79.5%)
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Atrributable AEs | 80 (33.6%) | 54 (46.2%)
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Withdrawn d/t AE | 14 (5.9%) | 14 (12.0%)
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | 2 cases of angioedema were reported in the lisinopril group (2/116 = 1.7%) vs. none in the candesartan group 6) Specific adverse events:
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | | [underlined: Candesartan] | [underlined: Lisinopril]
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Dizziness/vertigo | 11.8% | 15.4%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Headache | 11.8% | 8.5%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Viral infection | 8.8% | 7.7%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Fatigue | 5.9% | 6.0
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Back pain | 5.5% | 5.1%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Resp infection | 5.5% | 9.4%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Pain | 5.0% | NR
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Cough | 4.6% | 23.1%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Myalgia | 4.2% | 6.0%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Nausea | 4.2% | NR
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Accident/injury | NR | 4.3%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | Pharyngitis | NR | 4.3%
McInnes, O’Kane, Istad, et al., 2000 #5680 | | | | | | | 7) Persistence/adherence: As assessed by tablet count, 90% of patients took 90–110% of study medications – similar in two treatment groups 8) Lipid levels: NR 9) Progression to type 2 diabetes:NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | Geographical location: Multicenter trial (France??, Spain ??) Study dates: NR Funding source: Bristol-Myers Squibb/Sanofi Interventions: - Irbesartan 75 mg (n = 98) - Enalapril 10 mg (n = 102) One capsule once a day between 6 and 10 a.m. If DBP at trough was≥ 90 mm at weeks 4 or 8, dosage was doubled (irbesartan increased from 150 mg, enalapril to 20 mg). If SBP remained ≥ 90 mm at week 8 doses doubled again (300 mg and 40 mg). Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 4-to 5-wk single-blind placebo lead-in period Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: - Eligible for inclusion: - Randomized: 200 - Began treatment: 200 - Completed treatment: 191 - Withdrawals/losses to followup: 9, 4 due to AEs, 3 at patient request, 2 lost to followup Age: Mean (SD): 58.3 Median: NR Range: 145 < 65 yr; 55 ≥ 65 yr; 15≥ 75yr Sex (n [%]): Female: 99 Male: 101 Race/ethnicity (n [%]): NR Baseline blood pressure: Measured by a standard calibrated mercury sphygmomanometer. Mean of 3 readings take 1 min apart used. Seated and standing readings taken. Baseline seated BP: | | | | | 1) Blood pressure: Numerical results not reported. Both groups: Statistically significant decreases from baseline trough SBP and DBP at all measured time points (weeks 2-12). No statistically significant difference between regimes with respect to decrease in SBP or DBP. Results consistent across both sexes and all age groups. Pts maintained on lowest doses: DBP decreased by 15 mm within 4 weeks with no further decreases. Patients whose dose was doubled once: Mean DBP decreased by 8 mm with lowest doses, but mean DBP was above 90 mm. Doubling was associated with additional decrease of 5 mm between wks 4 and 8 for both groups, resulting in a decrease from baseline of 13 mm with little change thereafter. Patients whose dose was doubled twice: DBP decreased by 5 mm and 1 mm in both groups, resulting in a total decrease from baseline of 11 mm and 8 mm in enalapril and irbesartan groups. At 12 wks: - Mean DBP was higher in those titrated than those maintained at lowest dosages. - 66% of irbesartan and 63% of enalapril group were normalized (DBP < 90mm). 2) Rate of use of a single antihypertensive agent for BP control (different doses): NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | [underlined: Enalapril] | [underlined: Irbesartan] | | | | Enalapril (%) (n = 102) | Irbesartan (%) (n = 98) | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | SBP: | 164.9 ± 12.8 | 163.9 ± 12.5 | | | Adverse drug experience | 26 | 19 | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | DBP: | 101.8 ± 4.2 | 101.0 ± 4.1 | | | AE | 43 | 45 | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | Concurrent medications (n [%]): NR (though see Exclusion criteria) Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR Inclusion criteria: - Lead-in medication consumption > 80% and < 120% - DBP on days 22–29 (or days 29 and 36) between 95 mm Hg and 110 mm Hg inclusive, values on each day not differing by more than 8 mm Hg - Age ≥ 18 yr Exclusion criteria: - Concomitant diseases or medications that would present a safety hazard or interfere with assessment of safety or efficacy of study medications - Women who were pregnant, lactating, or of child-bearing potential | | | | | Serious AE | 1.0 | 4.1 | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | | | | | Discontinued | 2.9 | 1.0 | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | | | | | 6) Specific adverse events: Patients with cough (%): Enalapril: 15% Irbesartan: 7% 7) Persistence/adherence: NR 8) Lipid levels:NR 9) Progression to type 2 diabetes:NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Mean change in lab parameters at week 12 (95% CI): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | | | | | | Enalapril n = 96 | Irbesartan n = 94 | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | | | | | Creatinine (mg/dL) | 0.03 (0 to 0.06) | 0.01 (−0.02 to 0.04) | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #6640 | | | | | | | 13) Proteinuria: NR | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | Geographical location: 37 sites in Australia, Denmark, Finland, and Israel Study dates: NR Funding source: AstraZeneca Interventions: Randomized to 1 of 4 groups by treatment in 2 x 12-week periods: - Candesartan/candesartan (n = 66) - Lisinopril/lisinopril (n = 64) - Candesartan/candesartan + lisinopril (n = 34) - Lisinopril/candesartan + lisinopril (n = 35) Doses were: candesartan 16 mg, lisinopril 20 mg Co-interventions: Some patients also received HCTZ 12.5, but protocol for giving this not described Study design: RCT, parallel-group (performed as a mixed study; analyzed as a parallel-group study) Blinding: - Patients: Yes (double-dummy) - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 24 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 199 - Began treatment: 198 - Completed treatment: NR - Withdrawals/losses to followup: 2 excluded from 12- and 24-wk analyses (1 never took study med, 1 provided no efficacy data); additional 53 excluded from 24-wk analysis (“most because their DBP was below 80 mm Hg”) Age: Mean (SD): 59.8 Median: NR Range: NR Sex (n [%]): Candesartan/lisinopril: Female: 99 (50%) Male: 98 (50%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after 5- min rest using automatic device (Omron HEM-705 CP). Mean of 3 measures separated by 2 min analyzed. | | | | | 1) Blood pressure: Mean post-treatment BP values NR (except in Figure 2) Mean reduction (95% CI) in seated trough BP at 12 wk: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Primary results (mean post-treatment values) NR; report only differences from baseline - 24-wk results not analyzed for candesartan vs. lisinopril, only the combination vs. each individual - Addition of HCTZ permitted, but protocol for this not described Applicability: - All patients had type 2 diabetes and microalbuminuria - Recruitment not described
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | [underlined: Candesartan (n = 99)] | [underlined: Lisinopril (n = 98)] | | | | Candesartan (n = 99) | Lisinopril (n = 98) | Adjusted* mean diff. between groups
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | SBP | 162.7 ± 17.7 | 162.6 ± 17.6 | | | SBP | 12.4 (9.1 to 15.8) | 15.7 (12.2 to 19.2)* | 3.3 (−1.5 to 8.2) p = 0.18
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | DBP | 96.0 ± 6.2 | 95.7 ± 6.2 | | | DBP | 9.5 (7.7 to 11.2) | 9.7 (7.9 to 11.5) | 0.02 (−2.3 to 2.7) p > 0.20
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | Concurrent medications (n [%]): Oral anti-diabetic drugs: “about 80%” of patients in both groups Insulin: 20% in both groups Comorbidities (n [%]): All patients with hypertension, diabetes type 2 and microalbuminuria Recruitment setting: Tertiary hospitals and primary care clinics Inclusion criteria: - Age 30–74 yr - Type 2 diabetes - Urinary albumin:creatinine ratio 2.5-25 mg/mmol, diastolic BP 90-110 mmHg after 2 and 4 wk of placebo, respectively Exclusion criteria: - BMI ≥ 40 kg/m^2^ - SBP > 200 mm Hg - Non-diabetic cause of secondary hypertension - Cardiovascular event < 6 mo - Serum creatinine ≥ 130 x6d mol/L in women and ≥ 150 x 6d ml/L in men - Serum potassium > 5.5 mmol/L - HbA1c > 10% - Pregnancy or potential pregnancy or breastfeeding | | | | | *Adjusted for center, treatment, baseline value, weight, and change in DBP Mean reduction (95% CI) in seated trough BP at 24 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | | Candesartan (n = 49) | Lisinopril (n = 46)
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | SBP | 14.1 (8.9 to 19.2) | 16.7 (11.4 to 21.9)
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | DBP | 10.4 (7.7 to 13.1) | 10.7 (8.0 to 13.5)
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | No statistical tests reported for comparison between candesartan and lisinopril monotherapies at 24 wk 2) Rate of use of a single antihypertensive agent for BP control: Number of patients given HCTZ in addition to study drugs at 12 wk: Candesartan: 18/99 (18%) Lisinopril: 27/98 (28%) Number of patients given HCTZ in addition to study drugs at 24 wk: Candesartan: 7/49 (14%) Lisinopril: 6/46 (13%) 3) Mortality: NR 4) Morbidity: NR 5) Safety: 14/197 stopped treatment due to AEs: 5 due to dizziness, weakness, or both (candesartan 2, lisinopril 2, combination 1); 3 due to cough (all lisniopril). Others not specified. 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: No clear changes in mean values for HbA1c from baseline to 12 or 24 wk in any of the treatment groups (no quantitative data reported) 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Mean post-treatment urinary albumin:creatinine ratios NR Mean reduction in urinary albumin:creatinine ratio (%, with 95% CI) at 12 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | Candesartan (n = 99) | Lisinopril (n = 98) | Adjusted* mean diff. between treatments
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | 30 (15 to 42) | 46 (35 to 56) | 30 (1 to 71) p = 0.58
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | *Adjusted for center, treatment, baseline value, weight, and change in DBP Mean reduction in urinary albumin:creatinine ratio (%, with 95% CI) at 24 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | Candesartan (n = 49) | Lisinopril (n = 46) | Adjusted* mean diff. between treatments
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | 24 (0 to 43) | 39 (20 to 54) | Not reported
Mogensen, Neldam, Tikkanen, et al., 2000 #5340 | | | | | | | *Adjusted for center, treatment, baseline value, weight, and change in DBP
Naidoo, Sareli, Marin, et al., 1999 #6140 | Geographical location: 21 centers in South Africa, Hungary, Czech Republic, Slovak Republic, Argentina, Brazil, and Colombia Study dates: NR Funding source: Merck Interventions: - Losartan 100 mg + HCTZ 25 mg (n =176) - Enalapril 10 mg ± HCTZ 25 mg (n =173) Dose titration and co-interventions: Beginning at wk 2, amlodipine 5 mg could be added if DBP > 105, with titration to 10 mg if DBP > 90 at next visit Patients with inadequate BP control (SBP > 220 and/or DBP > 120 or increased > 15 from baseline) at 2 successive measurements at least 3 days apart were discontinued from the trial Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2 days no meds Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 349 - Began treatment: 325 - Completed treatment: 311 - Withdrawals/losses to followup: 38, some before and some after starting treatment (12 due to AEs, 12 due to protocol violations, 7 lost to followup, 5 lack of cooperation, 2 insufficient response) Age: Mean (SD): 53.25 Median: NR Range: NR Sex (n [%]): Female: 201 (58%) Male: 148 (42%) Race/ethnicity (n [%]): Caucasian: 174 (50%) Black: 98 (28%) Other: 77 (22%) Baseline blood pressure: Seated trough BP measured 3 times after a 5-min rest using a standard mercury sphygmomanometer; average of 3 readings used | | | | | 1) Blood pressure: Mean BP at 12 wk (entire sample): | | | | | General comments: - Patients with inadequate BP control (SBP > 220 and/or DBP > 120 or increased > 15 from baseline) at 2 successive measurements at least 3 days apart were discontinued from the trial Quality assessment: Overall rating: Fair Comments: - Varying numbers of patients reported in text and tables - 12-wk outcomes compared with prestudy treatment in primary statistical analysis Applicability: - Recruitment setting not described - Extensive exclusion criteria
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | Losartan/ HCTZ | Enalapril/ HCTZ | | | | Losartan/HCTZ (n = 173) | Enalapril/HCTZ (n = 173)
Naidoo, Sareli, Marin, et al., 1999 #6140 | | SBP | 162.9 ± 16.1 | 163.8 ± 16.1 | | | SBP | 139.7 ± 17.6 | 140.5 ± 15
Naidoo, Sareli, Marin, et al., 1999 #6140 | | DBP | 104.2 ± 6.3 | 103.6 ± 7.4 | | | DBP | 88.7 ± 10.1 | 88.4 ± 8.3
Naidoo, Sareli, Marin, et al., 1999 #6140 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Moderate or severe hypertension (DBP > 105) - Inadequate control on 2 or more agents (DBP > 90) - At least on drug-related symptom that might be alleviated by medication switch Exclusion criteria: - On ACEI prior to study start - Serious AE on ACEI, diuretic, or ARB - Malignant or secondary hypertension - SBP > 220 - Significant CV, GI, hepatic, or blood/coagulation disorders - Unstable diabetes - Obesity (arm girth > 41 cm) - Potassium < 3.5 or > 5.5 mEq/L - Serum creatinine > 150 umol/L - Bun > 12.5 mmol/L - Alanine or aspartate amino-transferase value > 50% upper limit normal - Proteinuria or hematuria - Cancer - AIDS - Absence of a kidney - Alcohol or drug abuse - Need for treatment with beta-blockers, psychotropics, antidepressants, cimetidine, oral contraceptives, steroids, corticotropin, or lithium | | | | | Mean BP for patients not receiving adjunctive amlodipine:
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | | Losartan/HCTZ (n = 129) | Enalapril/HCTZ (n = 124)
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | SBP baseline | 159.8 ± 13.7 | 161.5 ± 15.1
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | SBP 12 wk | 137.3 ± 16.6 | 139.2 ± 14.6
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | DBP baseline | 103.0 ± 5.8 | 103.2 ± 7.0
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | DBP 12 wk | 87.1 ± 10 | 87.5 ± 8.7
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Note: Ns reported above are as given in the relevant data tables; varying figures given in text and other tables Authors reported that “both regimens were effective in black (n = 54 losartan/HCTZ; n = 44 enalapril/HCTZ) and non-black patients (data not shown)” BP control rates (control not clearly defined): Losartan/HCTZ: 63% Enalapril/HCTZ: 58.4% 2) Rate of use of a single antihypertensive agent for BP control: NA; all patients taking a combination agent ± additional therapy 3) Mortality: NR 4) Morbidity: NR 5) Safety: No. of patients with ≥ 2 drug-related AEs: Losartan/HCTZ: 29 (16.5%) Enalapril/HCTZ: 37 (21.4%) Withdrawals due to AEs: Losartan/HCTZ: 5 (2.8%) Enalapril/HCTZ: 7 (4.0%) Withdrawals due to drug-related AEs: Losartan/HCTZ: 3 (1.7%) Enalapril/HCTZ: 3 (1.7%) No serious AEs judged to be drug-related 6) Specific adverse events: AEs not necessarily drug-related:
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | | Losartan/ HCTZ (n = 173), % | Enalapril/ HCTZ (n = 170), %
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Headache | 19.1 | 20.6
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Palpitations | 15.6 | 13.5
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Tired | 14.5 | 17.1
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Dizzy | 11.0 | 5.3
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Nervous | 12.1 | 9.4
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Flushing | 10.4 | 6.5
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Weakness | 9.2 | 7.1
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Swollen ankles | 5.8 | 5.3
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Muscle pain | 6.4 | 8.8
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Cough | 6.9 | 16.5*
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | Cold hands/feet | 6.4 | 7.6
Naidoo, Sareli, Marin, et al., 1999 #6140 | | | | | | | * p = 0.005, enalapril/HCTZ vs. losartan/HCTZ 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Neutel, Frishman, Oparil, et al., 1999 #5930 | Geographical location: 44 centers across US Study dates: NR Funding source: NR Interventions: - Telmisartan 40–160 mg qd (n = 385) - Lisinopril 10–40 mg qd (n = 193) Dosage titration and co-interventions: At wk 4, patients with uncontrolled DBP (≥ 90 mm Hg) were titrated to dose level 2 (telmisartan 80 mg, lisinopril 20 mg); if DBP still uncontrolled at wk 8, then titrated to dose level 3 (telmisartan 160 mg, lisinopril 40 mg). If DBP still uncontrolled at wk 12, but DBP reduced by ≥ 10 mm Hg from baseline, then HCTZ 12.5 mg added; remaining uncontrolled patients dropped from study. For patients on HCTZ, this could be titrated up to 25 mg if BP control lost during maintenance phase. If DBP ≥ 90 mm Hg on 2 consecutive study visit while patient taking max dose of HCTZ, then patient dropped from study Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: No Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 14-day withdrawal of previous antihypertensive med; 4-wk placebo run-in Duration of treatment: 48 wk after dose titration achieved Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 578 - Began treatment: 578 - Completed treatment: 448? - Withdrawals/losses to followup: 136 during dose-titration period (125 treatment failures, 11 no post-randomization BP data); 25 during maintenance phase (protocol deviations or invalid data) Age: Mean (SD): 53.5 Median: NR Range: NR Sex (n [%]): Female: 195 (34%) Male: 383 (66%) Race/ethnicity (n [%]): White: 433 (75%) Black: 102 (18%) Hispanic: 35 (6% Other: 8 (1%) Baseline blood pressure: Supine BP measured 3 times at 2-min intervals after patient rested in supine position for 5 min using mercury sphygmomanometer; average of 3 readings used | | | | | 1) Blood pressure: Mean change in BP at 48 wk (in mm Hg; all analyzable completers, n’s uncertain): | | | | | General comments: - Study excluded large number of patients post-randomization who failed to respond to treatment (DBP ≥ 90) Quality assessment: Overall rating: Fair Comments: - Randomization not described - Large number of non-responders excluded post-randomization - N’s unclear for many outcomes Applicability: - Recruitment not described - Non-responders excluded during study - Supine BP used
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | Telmisartan | Lisinopril | | | | Telmisartan | Lisinopril
Neutel, Frishman, Oparil, et al., 1999 #5930 | | SBP | 153.4 | 152.5 | | | SBP | −21.1 | −19.3
Neutel, Frishman, Oparil, et al., 1999 #5930 | | DBP | 100.8 | 100.5 | | | DBP | −16.3 | −15.4
Neutel, Frishman, Oparil, et al., 1999 #5930 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR- 44 centers Inclusion criteria: - Mean supine DBP 95–114 on placebo (run-in period) Exclusion criteria: - Secondary hypertension - Patients excluded at various points during study if DBP ≥ 90 | | | | | p = NS Mean change in BP at 48 wk among patients who completed on monotherapy (in mm Hg; n’s uncertain):
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | | Telmisartan | Lisinopril
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | SBP | −17.7 | −18.6
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | DBP | −15.9 | −15.5
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Telmisartan: 44% Lisinopril: 48% 3) Mortality: NR 4) Morbidity: NR 5) Safety: Drug-related AEs: Telmisartan: 28% Lisinopril: 40% p = 0.001 Discontinuations due to cough: Telmisartan: 0.3% Lisinopril: 3.1% p = 0.007 Discontinuations due to angioedema: Telmisartan: 0 Lisinopril: 2 patients 6) Specific adverse events: AEs considered to be drug-related:
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | | Telmisartan (n = 385), % | Lisinopril (n = 193), %
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Impotence | 3 | 2
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Headache | 5 | 6
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Fatigue | 4 | 7
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Cough | 3 | 7*
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Dizzy | 7 | 8
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | Dyspepsia | 0 | 2
Neutel, Frishman, Oparil, et al., 1999 #5930 | | | | | | | *p = 0.18 vs. telmisartan 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Rabbia, Silke, Carra, et al., 2004 #12280 | Geographical location: NR; investigators from Italy and Ireland Study dates: NR Funding source: No external funding Interventions: - Fosinopril 10–20 mg (n = 19) - Irbesartan 150–300 mg (n = 19) - Atenolol 50–100 mg (n = 20) All once daily at 8 am Doses doubled if office BP was ≥ 140/90 mm No sodium or liquid intake restriction Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: No Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo-run-in period Duration of treatment: 14 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 58 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean (SD): 38 ± 10 yr Median: NR Range: NR Sex (n [%]): Female: 27 Male: 31 Race/ethnicity (n [%]): NR Baseline blood pressure: Office BP measured 3 times by same physician in sitting position after 10 min of rest using a mercury sphygmomanometer, disappearance of phase V Korotkoff sound = diastolic pressure Baseline values: | | | | | 1) Blood pressure: Office BP at 14 wk (p < 0.001 for all comparisons with baseline): | | | | | General comments: - No racial distribution - Setting of study; no description (country? system? center selection? study clinicians?) - No data regarding numbers of patients screened, eligible for inclusion, or lost to followup Quality assessment: Overall rating: Fair Comments: - Setting of trial not described - Single-blind Applicability: - Race of patients not mentioned
Rabbia, Silke, Carra, et al., 2004 #12280 | | | Fosinopril | Irbesartan | | | | Fosinopril | Irbesartan
Rabbia, Silke, Carra, et al., 2004 #12280 | | SBP: | 152 ± 11 | 151 ± 11 | | | SBP: | 129 ± 7 | 133 ± 9
Rabbia, Silke, Carra, et al., 2004 #12280 | | DBP: | 97 ± 7 | 97 ± 6 | | | DBP: | 85 ± 4 | 87 ± 8
Rabbia, Silke, Carra, et al., 2004 #12280 | | ABPM obtained for 24 hr (results also reported) Concurrent medications (n [%]): None allowed during study Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Never treated mild hypertension with no evidence of target organ damage - SBP and DBP were ≥ 140 and ≥ 90 mm, respectively, on 3 consecutive days (3 measurements/day separated by 10-mm interval) after 15 min sitting position Exclusion criteria: - Clinical, biochemical, ECG or radiological evidence of end-organ damage or reported history of coronary artery disease - History of heavy alcohol consumption - Sec. hypertension def. as ABPM < 130/80 with persistently elevated office BP) and poor sleep quality during ABPM - No medications allowed during study | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: Nr 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Ragot, Ezzaher, Meunier, et al., 2002 #3630 | Geographical location: 105 outpatient French Centers Study dates: NR Funding source: NR Interventions: - Telmisartan 40–80 mg (n =220) - Perindopril 4–8 mg (n = 221) Doses doubled at 6 wk if necessary Study design: RCT, parallel-group Blinding: - Patients: NR - Providers: NR - Assessors of outcomes: No – patients self measure BP Was allocation concealment adequate?: Yes - IVRS Baseline/run-in period: 3-wk run-in placebo period sitting DBP ≥ 90 and ≤ 110 and SBP < 180 Duration of treatment: 12 wk Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: 671 - Eligible for inclusion: 441 - Randomized: 441 - Began treatment: 441 - Completed treatment: NR - Withdrawals/losses to followup: 73, 5 no BP measurements on treatment, 1 did not receive study med, 54 due to poor quality self BP measurement, 13 due to unspecified protocol violations - Per protocol population = 368 Age: Mean (SD): 55.3 ± 11.8 Median: NR Range: NR Sex (n [%]): Female: 197/435 (45%) Male: 238/435 (ITT pop) (55%) Race/ethnicity (n [%]): 421/435 = 97.5% white Baseline blood pressure: Trough office BP assessed using semiautomatic device (OMRON 705 CP); 3 measurements taken at 1-min intervals with patient sitting and after 5 min rest; mean analyzed | | | | | 1) Blood pressure: Mean trough office BP at 12 wk (taken from Fig 3; SDs not reported): | | | | | General comments: - Focus of article was comparison of self-measurement of BP and office measurement Quality assessment: Overall rating: Poor Comments: - Not blinded - Large number of patients (n = 59) excluded from per-protocol analysis due to poor quality self-measurement of BP Applicability: - Results are more applicable than most of HTN trials review in that co-morbidities are presented in baseline table
Ragot, Ezzaher, Meunier, et al., 2002 #3630 | | | Telmisartan (n = 217) | Perindopril (n = 218) | | | | Telmisartan (n = 217) | Perindopril (n = 218) | P-value
Ragot, Ezzaher, Meunier, et al., 2002 #3630 | | SBP | 158 ± 13 | 159 ± 13 | | | SBP | 144.0 | 148.0 | p < 0.05
Ragot, Ezzaher, Meunier, et al., 2002 #3630 | | DBP | 98 ± 6 | 98 ± 6 | | | DBP | 88.7 | 91.3 | p < 0.005
Ragot, Ezzaher, Meunier, et al., 2002 #3630 | | Concurrent medications (n [%]): Anti-HTN therapy prior to study entry: 236 (54%) Comorbidities (n [%]): Obesity 111 (25.5%) History of CV events 58 (13.5%) Type II DM 27 (6.5%) Recruitment setting: Outpatient French clinics Inclusion criteria: - Age ≥ 18 yr - Mild-moderate hypertension - Inadequate BP control or treatment side effect - 3-wk run-in placebo period sitting DBP ≥ 90 and ≤ 110 and SBP < 180 Exclusion criteria: - Patients with self BP measurement of poor quality during run-in period, poor compliance with treatment during run-in period - History of non response to ACEI or ARB - Suspicion of secondary HTN - Biliary disease - Non-postmenopausal women not using reliable contraception | | | | | Mean decrease in trough office DBP from baseline to 12 wk: Telmisartan: − 8.8 mm Hg Perindopril: −6.3 mm Hg p = 0.002 Adjusted mean difference (telmisartan vs. perindopril) for reduction in trough office SBP was −3.4 mm Hg (p = 0.016). Mean decreases NR. Normalized SBP at 12 wk (SBP < 140 mm Hg): Telmisartan: 97/217 (45%) Perindopril: 67/218 (31%) p < 0.005 Normalized DBP at 12 wk (DBP < 90 mm Hg): Telmisartan: 122/217 (56%) Perindopril: 96/218 (44%) p < 0.01 Results for self-BP measurement also reported 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 74 (34%) Perindopril: 70 (32%) 6) Specific adverse events: Cough: Telmisartan: 2 (< 1%) Perindopril: 12 (5%) p = 0.007 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | Geographical location: Krakow, Poland Study dates: NR Funding source: University grant Interventions: - Quinapril 20 mg qd (n = 38 BP responders) - Losartan 100 mg (50 mg bid) (n = 24 BP responders) - Amlodipine 10 mg qd (n = 37 BP responders) Dose titration and co-interventions: None, as subjects represent subgroup from larger trial who responded (BP ≤ 140/90 mm Hg) to monotherapy at 3 mo Study design: RCT, parallel-group Blinding: - Patients: No - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk antihypertensive-free run-in period Duration of treatment: 6 mo Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 118 (for the larger study) - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR Age (n = 118 larger trial): Mean (SD): 53.7 ± 9.06 Median: NR Range: NR Sex (n [%]; n = 118 larger trial)*: Female: 64 (54%) Male: 54 (46%) Race/ethnicity (n [%]): NR, but presumably 100% white Baseline blood pressure: Mean of 3 sphygmomanometer measurements “in standard conditions” Mean baseline values: | | | | | 1) Blood pressure: Mean BP at 3 mo: | | | | | General comments: - Subgroup analysis of patients from a larger trial who responded to monotherapy at 3 mo (99/118) - Focus of article is effect of treatment on pulse wave velocity and plasma collagen markers Quality assessment: Overall rating: Poor Comments: - No information on recruitment setting, exclusion criteria, or comorbidities - No data on safety/AEs - Inclusion of only responders to monotherapy biases the results toward the null hypothesis of no difference in BP response, especially since there were fewer responders in the losartan group Applicability: - Subgroup of patients who responded to monotherapy - No information on recruitment setting, exclusion criteria, or comorbidities
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | | Quinapril (n = 38) | Losartan (n = 24) | | | | Quinapril (n = 38) | Losartan (n = 24)
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | SBP | 154 ± 22.5 | 155 ± 18.6 | | | SBP | 141 ± 23.7 | 132 ± 15.8
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | DBP | 97 ± 14.1 | 91 ± 13.5 | | | DBP | 92 ± 8.7 | 83 ± 9.2
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Mild to moderate hypertension according to WHO/ISH guidelines - BP adequately controlled (BP ≤ 140/90 mm Hg at 3 mo) on study drug monotherapy Exclusion criteria: NR | | | | | Mean BP at 6 mo:
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | | | | | | | Quinapril (n = 38) | Losartan (n = 24)
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | | | | | | SBP | 113 ± 14.6 | 125 ± 16.8
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | | | | | | DBP | 86 ± 7.1 | 84 ± 8.1
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #3320 | | | | | | | No significant differences between groups for decrease from baseline at either timepoint (p-values NR) 24-hr ABPM values also reported 2) Rate of use of a single antihypertensive agent for BP control: NA (response to monotherapy was the criterion for inclusion in this subgroup report) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Measured but NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LVMI was comparable across groups at baseline (116.9 ± 23.9 g/m^2^) and did not change at 6 mo for any of the groups (data not shown) 12) Creatinine/GFR: NR 13) Proteinuria: NR
Robles, Angulo, Grois, et al., 2004 #12300 | Geographical location: Badajoz, Spain Study dates: NR Funding source: NR Interventions: - Irbesartan 150 mg/day (n = 15) - Fosinopril 20 mg/day (n = 15) After 4 weeks: If BP ≥ 140/90 titrated by adding 12.5mg/day After 8 weeks: Non-controlled patients excluded Sodium intake limited Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: NR - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: After withdrawal of any antihypertensive therapy, if needed, eligible patients entered a 2-week washout phase Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 30 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean: 61.3 yr Median: NR Range: NR Sex (n [%]): Female: 15 Male: 15 Race/ethnicity (n [%]): NR Baseline blood pressure: Method of assessment NR | | | | | 1) Blood pressure: BP at 12 wk (method of assessment NR; p < 0.001 for all comparisons vs. baseline): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Setting and some of the subjects not described Applicability: - Primary objective: effect of drugs on hematopoiesis - Setting and some of the subjects not described
Robles, Angulo, Grois, et al., 2004 #12300 | | | [underlined: Irbesartan] | [underlined: Fosinopril] | | | | [underlined: Irbesartan] | [underlined: Fosinopril]
Robles, Angulo, Grois, et al., 2004 #12300 | | SBP: | 157.7 ± 11.2 | 147.9 ± 11.7 | | | SBP: | 131.0 ± 8.7 | 132.2 ± 12.4
Robles, Angulo, Grois, et al., 2004 #12300 | | DBP: | 94.1 ± 5.6 | 92.3 ± 6.3 | | | DBP: | 82.7 ± 4.2 | 84.0 ± 5.4
Robles, Angulo, Grois, et al., 2004 #12300 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Mild or moderate essential HTN (BP ≥ 140/90 and < 180/100) Exclusion criteria: - Creatinine ≥ 1.5 mg/dL - Unstable angina - MI/stroke in last 3 mo - Heart failure - Hypokalemia - COPD - Hematological disease - Hb ≤ 13 gm or >17 gm - Hypersensitivity to test drugs - Pre-menopausal women | | | | | 2) Rate of use of a single antihypertensive agent for BP control: HCTZ was added to 6 pts with inadequate BP control at 4 wk (3 in Irb gp) and 8^th^ wk (2 in Irb gp and 1 in Fos gp) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | Geographical location: Multicenter, with sites in Spain, Austria, Brazil, Czech Republic, China, Colombia, Croatia, Dominican Republic, Ecuador, Jamaica, Mexico, Pakistan, Peru, Russia, Slovak Republic, Slovenia, Taiwan, Ukraine, UAE Study dates: NR Funding source: Merck & Co Interventions: - Losartan 50–100 mg (n = 192) - Captopril 25 mg twice daily-50 mg twice daily (n = 204) Dose titration and co-interventions: Titrated to higher dose at 6 wk if seated DBP ≥ 90; no other antihypertensives allowed Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 1-wk drug washout; 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 396 - Began treatment: 396 - Completed treatment: 356 - Withdrawals/losses to followup: 40 (17 due to AEs, 7 lost to followup, 7 insufficient response, 7 protocol violations, 2 uncooperative) Age: Mean (SD): 51.4 (10.9) Median: NR Range: NR Sex (n [%]): Female: 174 (44%) Male: 222 (56%) Race/ethnicity (n [%]): Black: 36 (9%) Non-black: 360 (91%) Baseline blood pressure: Trough seated BP assessed using mercury sphygmomanometer after 5-min rest; average of 3 readings | | | | | 1) Blood pressure: Main results in Figure 1 (change in seated DBP) and Figure 2 (change in seated SBP), but mean posttreatment BP values NR in tables or text. Mean change in seated BP from baseline to 12 wk: | | | | | General comments: - Patients withdrawn if DBP not ≥ 95 during placebo run-in period resulting in some potential exclusions - Primary outcome was change in DBP/SBP, but one wonders if this was established a priori since final SBP/DBP are not reported in study. Quality assessment: Overall rating: Fair Comments: - Numbers screened and eligible NR Applicability: - Minimal racial diversity (91% Caucasian) - Recuitment setting(s) not described - Minimal comorbities in study population; difficult to extrapolate to the general population
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | [underlined: Losartan] | [underlined: Captopril] | | | | Losartan (n = 190) | Captopril (n = 203) | P-value
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | SBP | 158.2 ± 16.5 | 157.2 ± 16.7 | | | SBP | −15.4 | −12.2 | = 0.023
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | DBP | 103.9 ± 6.5 | 103.2 ± 7.1 | | | DBP | −11.5 | −9.3 | = 0.010
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | Concurrent medications (n [%]): Other BP meds not permitted Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Adult male and female outpatients - Mild-to-moderate HTN (DBP 90–115 before placebo, then 95–115 after 2 & 4 wks on placebo during run-in - No concurrent medical conditions - No therapy that might affect BP Exclusion criteria: - Malignant or secondary HTN - Untreated thyrotoxicosis or hypothyroidism - Significant cardiovascular, cerebrovascular, hepatic, renal, GI, hematologic, pulmonary, or neurologic disorders - Uncontrolled diabetes - Concurrent disease that would preclude participation or survival (e.g., AIDs or neoplasm) - Alcohol or drug abuse - Clinically significant lab values outside normal range (e.g., serum K < 3.5 or > 5.5 mol/L - Women who were pregnant or lactating - Known sensitivity to captopril or other ACEIs - Concomitant therapy with other investigational drugs, beta-blockers, steroids, ACTH, or lithium | | | | | BP control rates at 12 wk (DBP < 90 or decrease in DBP from baseline of ≥ 10 mm Hg): Losartan: 60.0% Captopril: 54.7% p > 0.10 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensives allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | | Losartan (n = 192) | Captopril (n = 204)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | ≥ 1 clinical AE | 63 (33%) | 83 (41%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | ≥ 1 drug-related clinical AE | 20 (10%) | 27 (13%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | ≥ 1 serious clinical AE | 4 (2%) | 10 (5%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | Withdrawn due to clinical AEs | 5 (3%) | 12 (6%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | ≥ 1 laboratory AE | 24 (13%) | 24 (12%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | ≥ 1 drug-related laboratory AE | 11 (6%)* | 3 (2%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | * p = 0.029; all other between-group comparisons NS Withdrawals for serious clinical AEs included 1 losartan for encephalopathy and HTN crisis, 1 captopril for HA with TIA and hemiparesis. Other withdrawals were “considered unrelated to study treatment.” Withdrawals for clinical AEs included 3 losartan for urticaria + pruritis, chest pain, taste perversion (first 2 related to study treatment); 9 captopril for pruritis, headache (2), vomiting, taste loss, dizziness with headache, rash, dyspnea with heart failure, anxiety with tachycardia (all but last one considered drug-related). Laboratory AEs included: losartan (increased ALT in 4, hyperbilirubinemia in 2, increased serum creatinine in 2, increased BUN in 1, hyperkalemia in 1); captopril (1 drug-related hyperuricemia and 1 hyperkalemia). 6) Specific adverse events:
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | | Losartan (n = 192) | Captopril (n = 204)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | Headache | 8% | 10%
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | Cough | 6% | 7%
Roca-Cusachs, Oigman, Lepe, et al., 1997 #6710 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: see above 13) Proteinuria: NR
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | Geographical location: Italy Study dates: NR Funding source: Takeda Italia Farmeceutici S.p.A., Rome, Italy Interventions: - Candesartan 8–16 mg (n = 66) - Enalapril 10–20 mg (n = 63) Dose titration/co-interventions: Patients started on lower dose of study drug; moved to higher dose if BP ≥ 130/85 after 6 wk. If BP still uncontrolled after 12 wk, HCTZ 12.5 mg added. If BP not controlled at 18 wk, HCTZ increased to 25 mg. Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 24 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 129 - Began treatment: 129 - Completed treatment: 118 - Withdrawals/losses to followup: 11 Age: Mean (SD): 58.4 Median: NR Range: 30 to 70 Sex (n [%]): Female: 36% Male: 64% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after 5-min rest; mean of 3 measurements taken at 1-min intervals BP measured using a mercury sphygmomanometer and a validated automatic device (Omron 705 CP) Baseline mean values NR (from Abstract; see also Figures 1 and 2): Candesartan: 148/90 ± 11/8 mm Hg Enalapril: 148/91 ± 12/8 mm Hg Concurrent medications (n [%]): NR Comorbidities (n [%]): Candesartan/Enalapril: No alcohol: 49%/52% No smoking: 83%/75% Retinopathy: 6%/3% Heart disease: 9%/13% Kidney disease: 2%/3% Recruitment setting: NR Inclusion criteria: - Grade 1 essential hypertension (SBP 140–159; DBP diastolic 90–99) at the end of 2-wk run-in period - Age 30–70 yr - Previous diagnosis of NIDDM with or without hypoglycemic therapy - Previously treated with antihypertensive drugs (including ACEs or ARBs) for ≤ 1 mo in the 3 mo preceding enrollment - If previously treated, enrolled only if did not tolerate or respond to previous antihypertensive medication Exclusion criteria: - Secondary hypertension - SBP > 159, DBP > 99 - IDDM, intolerance or contraindications to study drugs - Use of study drug within 4 wk of enrolment - Major cardiac arrhythmias, hemodynamically relevant valvular heart disease, AV blocks grade 2 or 3 - CHF (NYHA II-IV) - MI, stroke, coronary surgery, TIA within previous 3 mo - Angina - Autonomic neuropathy - PVD with lesions - Known renal artery stenosis, kidney transplantation - Serum creatinine > 1.6 mg/dL - Severely impaired liver function, serum sodium ≤ 130 mmol/L, serum K ≤ 3.6 mmol/L | | | | | 1) Blood pressure: Mean BP at 24 weeks (from Abstract; not clear whether taken using sphygmomanometer [see Figure 1] or automatic device [see Figure 2]): Candesartan: 132/82 ± 12/7 mm Hg Enalapril: 131/85 ± 14/6 mm/Hg p = NS BP response rates at 24 wk (response not defined): Candesartan: 70.5% Enalapril: 71.9% p = NS 2) Rate of use of a single antihypertensive agent for BP control: Monotherapy at 18–24 weeks: Candesartan: 59% Enalapril: 63.8% 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AEs: Candesartan: 27/66 (40.9%) Enalapril: 31/63 (49.2%) p = NS 1 non-drug-related serious AE (diabetes decompensation in patient in candesartan group) 6) Specific adverse events: NR 7) Persistence/adherence: Mean compliance: Candesartan: 98.2 ± 13.16% Enalapril: 97.8 ± 13.67% 8) Lipid levels: Triglycerides (mg/dL): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | | Candesartan (n = 60) | Enalapril (n = 57) | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | Baseline | 145.5 ± 79.5 | 143.9 ± 111.5 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | 24 wk | 159.1 ± 95.3 | 154.8 ± 160.5 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | Total cholesterol (mg/dL): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | | Candesartan | Enalapril | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | | (n = 60) | (n = 57) | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | Baseline | 212.8 ± 39.4 | 221.2 ± 37.0 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | 24 wk | 210.0 ± 35.4 | 228.1 ± 37.3 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | LDL cholesterol (mg/dL): | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | | Candesartan | Enalapril | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | | (n = 60) | (n = 57) | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | Baseline | 142.4 ± 34.8 | 152.0 ± 35.5 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | 24 wk | 140.9 ± 28.8 | 157.5 ± 34.9 | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1480 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: No difference (data not reported) 13) Proteinuria: Candesartan: 33.9 (92.6) Enalapril: 58.3 (195.3) | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Assembly of patients not described Applicability: - Patient identification, study site not clear - All patients had NIDDM
Ruff, Gazdick, Berman, et al., 1996 #7110 | Geographical location: 12 centers in the U.S. Study dates:NR Funding source: NR, but authors from Merck Interventions: - Losartan 50 mg daily; therapy intensified at 2-wk intervals for DBP≥ 90 (see below) (n = 50) - Enalapril 20 mg daily; therapy intensified at 2-wk intervals for DBP≥ 90 (n = 25) Titration protocol: 1) Double dose of study med 2) Add hctz 25mg daily 3) Add atenolol 50 mg daily and titrate to 100 mg daily or add dihydropyridine calcium channel blocker 4) Add other therapy at discretion of investigator Study design: RCT, parallel-group Blinding: - Patients: Yes (double-dummy) - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 7-day baseline washout. No run-in period Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 75 (2:1 losartan:enalapril) - Began treatment: 75 - Completed treatment: 67 - Withdrawals/losses to followup: 8 Age: Mean (SD): 50.9 (11.6) Median: NR Range: 23–74 Sex (n [%]): Female: 30 (40%) Male: 45 (60%) Race/ethnicity (n [%]): White− 40 (53%) Black− 32 (43%) Hispanic – 2 (3%) Native American – 1 (1%) Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomanometer after 5 min rest; average of 3 readings taken at 1-min intervals | | | | | 1) Blood pressure: Seated trough BP: | | | | | General comments: - Main limitation is lack of description of numbers screened and eligible Quality assessment: Overall rating: Good Applicability: - Exclusion criteria limit the applicability to a larger hypertension population - Short time frame - Non-meaningful endpoints beyond BP response and tolerability
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | [underlined: Losartan] | [underlined: Enalapril] | | | | Los- pre | Los- 12 wk | Enal - pre | Enal - 12 wk
Ruff, Gazdick, Berman, et al., 1996 #7110 | | SBP | 173.7 ± 14.5 | 176.5 ± 14.9 | | | SBP | 173.7 (14.5) | 140.3 (16.1) | 176.5 (14.9) | 133.8 (14.5)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | DBP | 118 ± 3.5 | 119 ± 3.1 | | | DBP | 118 (3.6) | 90.8 (8.7) | 119 (3.1) | 88.4 (5.1)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | Seated response peak BP also collected (5–8 hr after administration) Concurrent medications (n [%]): Antihypertension meds stopped at baseline. No other meds reported. Comorbidities (n [%]): NR Recruitment setting: 12 US centers (no other info) Inclusion criteria: - Sitting trough DBP 115–130 Exclusion criteria: - Females of childbearing potential were included only w/neg preg test w/I 72yrs and monthly thereafter - DM if fasting sugar >180 - Secondary htn - Serious heart, liver, or renal disease - Any other active medical condition or tx that might affect bp or confound results of study - ASA, acetaminophen, nsaids and low dose TCAs had to be OK’d by study monitor | | | | | All pre-post differences significant at P < 0.05 Diff in SBP between losart and enal (p = 0.037) Diff in DBP between losart and enal (p = 0.051) BP response: By 12 wk, 98% of losartan patients and 100% of enalapril patients had a DBP < 90 or a reduction of DBP ≥10 (between-group difference not significant) Subgroup analysis reported for black vs. non-black. “Similar reductions in black compared with non-black patients” SBP:
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Non-black | | Black
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Losart | Enal | Losart | Enal
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Pre- | 172.5 (15.4) | 180.3 (15.3) | 175.2 (13.6) | 170.9 (12.9)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Post- | 141.5 (16.8) | 135.4 (14.9) | 138.6 (15.8) | 131.4 (14.2)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Chan ge | −31.0 (16.2) | −44.9 (16.6) | −36.6 (19.5) | −39.5 (20.0)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | DBP:
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Non-black | | Black
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Losart | Enal | Losart | Enal
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Pre- | 118.2 (3.2) | 118.6 (2.5) | 118.9 (3.9) | 120.3 (3.7)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Post- | 91.1 (10.0) | 88.2 (4.4) | 90.5 (6.9) | 88.7 (6.2)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Change | −27.1 (8.9) | −30.4 (4.9) | −28.4 (6.8) | −31.6 (5.0)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: At week 12: 3/50 in losartan group (6%) 4/25 in enalapril group (16%) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Losartan (n = 50) | Enalapril (n = 25)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Adverse event | 35 (70%) | 19 (76%)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | 6/50 pts withdrew from losartan 2/25 pts withdrew from enalapril 6) Specific adverse events:
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | | Losartan (n = 50) | Enalapril (n = 25)
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Headache | 22% | 20%
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Dizziness | 14% | 12%
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Edema | 4% | 12%
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | Cough | 8% | 12%
Ruff, Gazdick, Berman, et al., 1996 #7110 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control:NR 11) LV mass/function: NR 12) Creatinine/GFR:NR 13) Proteinuria:NR
Ruilope, Jager, and Prichard, 2001 #4640 | Geographical location: 48 centers in France, Germany, Ireland, The Netherlands, Spain, Sweden, and UK Study dates: NR Funding source: NR, but contact author employed by Solvay Pharma Interventions: - Eprosartan 600 mg qd (titrated to 800 mg qd after 3 wk if SBP > 140 mm Hg) (n = 168) - Enalapril 5 mg qd (titrated to 10, then 20 q 3 wk if SBP > 140 mm Hg) (n = 163) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: Single-blind, placebo run-in 3–4 wks Duration of treatment: 12 weeks Duration of post-treatment followup: 7–10 days after treatment period | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 396 - Randomized: 334 - Began treatment: 334 - Completed treatment: 290 - Withdrawals/losses to followup: NR; 3 patients had no valid efficacy data and were excluded from analysis; reasons for other discontinuations NR - Population analyzed = 331 (eprosartan 168, enalapril 163) Age: Mean (SD): 73 Median: NR Range: NR Sex (n [%]): Female: 181 (54%) Male: 153 (46%) Race/ethnicity (n [%]): Caucasian 332 (99%) Baseline blood pressure (± SEM): Trough BP measured 3 times at 2-min intervals after patient seated for at least 5 min using mercury or mercury-calibrated sphygmomanometer; mean of 3 readings used | | | | | 1) Blood pressure: Mean post-treatment BP values NR Mean changes from baseline (at 12 wk): | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | [underlined: Eprosartan] | [underlined: Enalapril] | | | | [underlined: Eprosartan] | [underlined: Enalapril] | [underlined: P-value] | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | Sit SBP | 176 ± 0.9 | 175 ± 0.9 | | | Sit SBP | −18.0 | −17.4 | 0.76 | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | Sit DBP | 98 ± 0.4 | 98 ± 0.4 | | | Sit DBP | −9.4 | −9.6 | 0.84 | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | Concurrent medications (n [%]): Any medication: Eprosartan: 69% Enalapril: 75.5% Other antihypertensive medication: Eprosartan: 8.8% Enalapril: 6.7% Comorbidities (n [%]): NR Recruitment setting: Not described Inclusion criteria: - Age ≥ 65 years - Essential HTN - Sitting SBP ≥ 160 mmHg and DBP 90–114 mmHg - Newly diagnosed or requiring change in treatment due to poor efficacy or tolerability Exclusion criteria: - Secondary HTN - Advanced hypertensive retinopathy - Sitting SBP > 210 mm Hg - MI or CVA < 90 days - CHF, angina - Poorly controlled diabetes - Significant renal or hepatic disease - Significant ventricular tachyarrhythmias -Severe disease (e.g., cancer) which could preclude participation or survival - Alcohol or drug abuse - Recent use of investigational drug - Concurrent use of MAOIs, tricyclics, phenothiazine derivatives, any medication know to affect BP, or sympathomimetic amines | | | | | Response rates (Sit SBP < 140 or 140–150 with decrease of ≥20 mm Hg from baseline; Sit DBP < 90 or 90–100 with decrease of ≥ 10 mm Hg from baseline); last available BP reading used: | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | | [underlined: Eprosartan] | [underlined: Enalapril] | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | SBP | 68/168 (41%) | 63/163 (39%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | DBP | 108/68 (64%) | 111/163 (68%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Other antihypertensive medication taken during trial: Eprosartan:8.8% Enalapril:6.7% 3) Mortality: 2 deaths, one in each group; neither was considered related to study medication 4) Morbidity: NR 5) Safety: | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | | [underlined: Eprosartan] | [underlined: Enalapril] | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | ≥1 AE | 61 (35.7%) | 83 (50.9%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Susp/prob. AE | 11 (6.4%) | 24 (14.7%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | 6) Specific adverse events: | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | | [underlined: Eprosartan] | [underlined: Enalapril] | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Headache | 7 (4.1%) | 10 (6.1%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Fatigue | 5 (2.9%) | 7 (4.3%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Diarrhea | 5 (2.9%) | 3 (1.8%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Injury | 4 (2.3%) | 2 (1.2%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Abdominal pain | 3 (1.8%) | 4 (2.5%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Dizziness | 3 (1.8%) | 5 (3.1%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Infection viral | 2 (1.2%) | 5 (3.1%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | Coughing | 1 (0.6%) | 10 (6.1%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | UTI | 0 (0%) | 5 (3.1%) | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #4640 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability: - Multinational, but virtually all Caucasian subjects
Saito, Asayama, Ohkubo, et al., 2004 #1860 | Geographical location: Japan (nationwide) Study dates: 2002 - Mar 2003 Funding source: Non-profit foundation, device manufacturers Interventions: CCB (n = 239) ACEI (n = 214) ARB (n = 200) Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes Was allocation concealment adequate?: Yes Baseline/run-in period: None Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: 1736 - Randomized: 1086 - Began treatment: NR - Completed treatment: 653 - Withdrawals/losses to followup: 433 had not completed ≥ 6 mo followup Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: NR Male: NR Race/ethnicity (n [%]): NR (presumably 100% Japanese) Baseline blood pressure: Home BP measured using automated device (Omron HEM-747IC-N) | | | | | 1) Blood pressure: Home values at 6 mo, measured using automated device: | | | | | General comments: - BP data from home monitoring, may not be comparable to clinic-based seated measurements - Rates of discontinuation and switching driven by protocol, rather than usual care, may be more reliable Quality assessment: Overall rating: Fair Comments: - Complicated treatment/switching algorithm - Drug intervention nested within what seems to primarily by a health services intervention - See above, under General comments Applicability: - Japanese ethnic population may not be generalizable to U.S.
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | [underlined: SBP] | [underlined: DBP] | | | | [underlined: SBP] | [underlined: DBP]
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | CCB | 149 ± 14 | 90 ± 10 | | | CCB | 134 ± 12 | 82 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | ACEI | 150 ± 14 | 89 ± 11 | | | ACEI | 136 ± 15 | 80 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | ARB | 149 ± 13 | 89 ± 10 | | | ARB | 134 ± 13 | 80 ± 9
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | Concurrent medications (n [%]): 0 [0%] Comorbidities (n [%]): NR Recruitment setting: Primary care practice Inclusion criteria: - Previously untreated patients ≥ 40 years of age - Home BP values ≥ 135/85 mmHg Exclusion criteria: NR | | | | | 2) Rate of use of a single antihypertensive agent for BP control: At 6 months: CCB: 34% (82/239) ACEI: 24% (51/214) ARB: 30% (60/200) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: At 6 months, switches determined by BP values and computerized treatment algorithm:
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | | | | | Drug | Continued | Switched | D/c’d
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | | | | | ARB | 89% | 9% | 2%
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | | | | | ACEI | 71% | 28% | 1%
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | | | | | CCB | 89% | 8% | 3%
Saito, Asayama, Ohkubo, et al., 2004 #1860 | | | | | | | 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Sato, Tabata, Hayashi, et al., 2003 #2640 | Geographical location: Ibaraki, Japan Study dates: NR Funding source: NR Interventions: Cross sectional cohort of patients treated with: - Trandolapril (n = 18) - Enalapril (n = 5) or - Candesartan (n = 26) If BP not controlled (< 130/85 mm Hg), then calcium antagonist, α1-blocker, and central-acting α2-stimulant added successively Study design: Cross-sectional cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA (patients were treated previously with ACEI or ARB for 11 ± 3 months) Duration of post-treatment followup: NA | Number of patients: 49 (cross-sectional cohort) Age: Mean (SD): 63.3 Median: NR Range: NR Sex (n [%]): Female: 23 (47%) Male: 26 (53%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated BP measured using a mercury sphygmomanometer after 15-min rest (average of 3 readings) Note: 15/49 patients (30.6%) normotensive Mean baseline BP values: | | | | | 1) Blood pressure: NR separately for hypertensive patients 2) Rate of use of a single antihypertensive agent for BP control: NR separately for hypertensive patients 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: ACEI: cough 2 patients No other clinical AEs observed 7) Persistence/adherence: NR 8) Lipid levels: NR separately for hypertensive patients 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR separately for hypertensive patients 11) LV mass/function: NR (LVMI not reported by treatment/hypertension status) 12) Creatinine/GFR: NR separately for hypertensive patients 13) Proteinuria: Mean changes in urinary albumin excretion (±SEM, mg/g creatinine), hypertensive patients only: | | | | | General comments: - 15/49 subjects (30.6%) were normotensive; limited results reported separately for hypertensive subjects Quality assessment: Overall rating: Poor Comments: - Results not separated by hypertension status - Cross-sectional without establishment of an inception cohort Applicability: - Limited to a single hospital in Japan - All patients had diabetic nephropathy stage 2 or 3A
Sato, Tabata, Hayashi, et al., 2003 #2640 | | | [underlined: ACEI] | [underlined: ARB] | | | | [underlined: ACEI (n = 16)] | [underlined: ARB (n = 18)]
Sato, Tabata, Hayashi, et al., 2003 #2640 | | SBP | 141 ± 13 | 142 ± 16 | | | Before | 417 ± 162 | 455 ± 166
Sato, Tabata, Hayashi, et al., 2003 #2640 | | DBP | 78 ± 11 | 79 ± 9 | | | After | 92 ± 37 | 99 ± 52
Sato, Tabata, Hayashi, et al., 2003 #2640 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): See Inclusion criteria Recruitment setting: Single hospital Inclusion criteria: - Clinical diagnosis of diabetic nephropathy stage 2 or 3A (defined by presence of either micro-albuminuria with urinary albumin excretion [UAE] 30–300 mg/g creatinine [stage 2] or overt proteinuria [UAE > 300 mg/g creatinine] with a glomerular filtration rate > 60 mL/min [stage 3A]) Exclusion criteria: None specified
Schieffer, Bunte, Witte, et al., 2004 #12330 | Geographical location: Hanover and Hamburg, Germany Study dates: NR Funding source: Sanofi-Synthelabo Interventions: - Enalapril 2 x 10 mg/day (gp A, ENAL) (n = 27) - Irbesartan 2 x150 mg/day (gp B, IRB) (n = 21) Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: NR Was allocation concealment adequate?: Yes (randomization list) Baseline/run-in period: NA Duration of treatment: 3 months Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 60 - Eligible for inclusion: - Randomized: 48 - Began treatment: 48 - Completed treatment: 47 - Withdrawals/losses to followup: 1 (enalapril; symptomatic hypotension); a further 11 patients were excluded from the analysis due to protocol violations Age: Mean (SD): 57.1 (weighted average) Median: NR Range: NR Sex (n [%]): Female: 12 Male: 36 Race/ethnicity (n [%]): NR Baseline blood pressure: | | | | | 1) Blood pressure: At 3 months (method of assessment NR): | | | | | General comments: None Quality assessment: Overall rating: Poor Comments: - Not clear all patients were hypertensive - No run-in period - LV results not quantified Applicability: - Race of patients not described
Schieffer, Bunte, Witte, et al., 2004 #12330 | | | [underlined: Enalapril] | [underlined: Irbesartan] | | | | [underlined: Enalapril] | [underlined: Irbesartan]
Schieffer, Bunte, Witte, et al., 2004 #12330 | | SBP: | 147 ± 35 | 143 ± 23 | | | SBP: | 133 ± 19* | 133 ± 22*
Schieffer, Bunte, Witte, et al., 2004 #12330 | | DBP: | 88 ± 16 | 84 ± 16 | | | DBP: | 83 ± 9** | 80 ± 12**
Schieffer, Bunte, Witte, et al., 2004 #12330 | | Method of assessment NR Concurrent medications (n [%]): 1 patient in each group received oral diabetes medication Comorbidities (n [%]): 4 patients receiving irbesartan and 6 receiving enalapril had diabetes Recruitment setting: NR (university hospital?) Inclusion criteria: - 6–8 weeks after coronary angioplasty - No symptoms of angina or heart failure Exclusion criteria: - Receiving ACE, ARB, HMG-CoA reductase inhibitor, NSAID (100 mg aspirin allowed) - CRF - LDL ser levels >150mg/dL - Hypotension (SBP < 90mm) | | | | | * p < 0.01 vs. baseline ** p < 0.05 vs. baseline 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: Reported to be no difference between groups (no numerical data reported) 12) Creatinine/GFR: NR 13) Proteinuria:NR
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #990 | Geographical location: 6 sites in The Netherlands Study dates: July 1998-Oct 2001 Funding source: AstraZeneca Interventions: - HCTZ 12.5 mg (n = 24) - Candesartan 8 mg (n = 24) - Lisinopril 10 mg (n = 22) Dose titration/co-interventions: Target BP = seated BP < 130/85 or SBP decrease > 10% with DBP < 85. If target BP not achieved, then following added consecutively: - HCTZ 12.5 mg - Doubling of study medication - Felodipine 5 mg - Metoprolol 50 mg - Doxazosin 2 mg - Felodipine 5 mg - Metoprolol 50 mg - Doxazosin 2 mg - Felodipine 5 mg - Metoprolol 100 mg - Doxazosin 4 mg Study design: RCT, parallel-group Blinding: - Patients: Yes (double-dummy) - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 1-mo run-in (patients treated with diet only); if on ACEIs, these were withdrawn for 3 months prior to the run-in period Duration of treatment: 4- to 6-mo BP titration period (continued until target BP achieved or until above treatment protocol exhausted), 12-mo study period Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 70 - Began treatment: 70 - Completed treatment: 60 - Withdrawals/losses to followup: 10 (9 due to AEs, 1 for unspecified reasons) Age (candesartan and lisinopril groups): Mean (SD): 61.0 Median: NR Range: NR Sex (candesartan and lisinopril groups; n [%]): Female: 27/46 (59%) Male: 19/46 (41%) Race/ethnicity (n [%]): 100% Caucasian Baseline blood pressure: Seated BP measured after 5 min of seated rest; mean of 3 consecutive measurements) | | | | | 1) Blood pressure: Mean seated BP at 12 mo: | | | | | General comments: - Comparatively complicated treatment protocol with multiple co-interventions (“aggressive antihypertensive therapy”) - Pre-study titration phase lasted until target BP achieved or until treatment options exhausted (4–6 mo) Quality assessment: Overall rating: Good Applicability: - No mention of site selection; not clear if all sites were hospital-based clinics - All patients had type 2 diabetes - 100% Caucasian study population
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #990 | | | Candesartan (n = 24) | Lisinopril (n = 22) | | | | Candesartan (n = 24) | Lisinopril (n = 22)
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #990 | | SBP | 151± 14 | 149 ± 9 | | | SBP | 133 ± 15 | 132 ± 12
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #990 | | DBP | 94 ± 10 | 93 ± 7 | | | DBP | 81 ± 11 | 80 ± 7
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #990 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics, newspaper advertisements Inclusion criteria: - Type II diabetes mellitus for ≥ 6 mo - Age 35 to 70 yr - Caucasian ethnicity - Urinary albumin excretion < 100 mg/24 hr Exclusion criteria: - Pregnancy or planned pregnancy - History of MI, angina, coronary artery bypass surgery, angioplasty, stroke, CHF, malignancy, or other serious illness - Serum creatinine > 140 μmol/L - BMI > 35 kg/m^2^ - Alcohol and/or drug abuse - Participation in other clinical trials | | | | | p = NS for between-group differences Percentage of patients achieving target BP (seated BP < 130/85 or SBP decrease > 10% with DBP < 85) after titration phase: Candesartan: 67% Lisinopril: 68% 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: None 4) Morbidity: NR 5) Safety: Withdrawals due to AEs: Candesartan: 3/24 (12.5%) Lisinopril: 1/22 (4.5%) AEs leading to withdrawal: Candesartan: Palpitations 1; dizziness 1; microalbuminuria 1 Lisinopril: Rise in creatinine 1 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: No change (data not shown) 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: No change in HbA1c (data not shown) 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Urinary albumin excretion decreased significantly at 12 mo vs. baseline in both groups, with no significant difference between groups (data shown only graphically [Figure 3])
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | Geographical location: Christchurch, New Zealand Study dates: NR Funding source: Merck Sharp and Dohme Interventions: - Losartan 50–100 mg daily (n = 15) - Enalapril 2.5–10 mg daily (n = 14 ) Dose titration/co-interventions: Both drugs titrated at discretion of treating MD/investigator Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NR Baseline/run-in period: 14-day washout of previous antihypertensive meds; no other run-in Duration of treatment: 120 days Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 29 - Began treatment: 29 - Completed treatment: 27 - Withdrawals/losses to followup: 2 withdrawals Age: Mean (SD): 45 (13) Median: NR Range: NR Sex (n [%]): Female: 14 (48%) Male: 15 (52%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated BP measured using a standard mercury sphygmomanometer; median of 3 readings | | | | | 1) Blood pressure: Mean seated BP (SD): | | | | | General comments: - One patient in the losartan group was excluded from analysis due to ineffective BP control Quality assessment: Overall rating: Poor Comments: - Ill-defined protocol - Not blinded - Missing information - Large BP differences in treatment groups at baseline (suggesting failure of randomization) Applicability: - Source of participants and recruitment not described - No information on AEs - All patients had renal parenchymal disease
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | [underlined: Losartan] | [underlined: Enalapril] | | | | Losart Pre- | Losart 120 days | Enal Pre- | Enal 120 days
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | SBP | 153 ± 18 | 141 ± 14 | | | SBP | 153 (18) | 138 (16) | 141 (14) | 134 (10)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | DBP | 100 ± 13 | 96 ± 13 | | | DBP | 100 (13) | 88 (8) | 96 (13) | 87 (10)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: - Hypertension - Renal parenchymal disease - Stable renal function Exclusion criteria: - Patients on diuretics at baseline - Require > 1 med for BP control at baseline | | | | | P < 0.01 for losartan SBP and DBP pre-/post- P < 0.01 for enalapril DBP pre-/post- (not SBP) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Generally not reported. 1 patient withdrew from enalapril arm due to cough. No other AEs reported. 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Mean creatinine clearance (mL/sec 1.73 m^2^):
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | | [underlined: Losartan] | [underlined: Enalapril]
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | Baseline | 1.88 (0.32) | 1.82 (0.21)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | 120 days | 1.90 (0.32) | 1.69 (0.21)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | Mean plasma creatinine (mmol/L):
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | | [underlined: Losartan] | [underlined: Enalapril]
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | Baseline | 0.11 (0.05) | 0.11 (0.04)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | 120 days | 0.11 (0.06) | 0.11 (0.05)
Shand, 2000 #5660 and Shand and Lynn, 2000 #12380 | | | | | | | 13) Proteinuria: NR
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | Geographical location: Osaka, Japan Study dates: Nov 1998 – April 2000 Funding source: Ministry of Education, Science, Sports, and Culture - Japan Interventions: Number of patients randomized to each treatment group NR - Losartan 50 mg daily (n = 10 completed) - Amlodipine 5 mg daily (n = 10 completed) - Enalapril 5 mg daily (n = 10 completed) No dose titration or co-interventions Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2 wk (intervention not described) Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 45 - Eligible for inclusion: 38 - Randomized: 38 - Began treatment: 38 - Completed treatment: 30 - Withdrawals/losses to followup: 8 Age: Mean (SD): 55 (3) Median: NR Range: 21–80 Sex (n [%]): Female: 11 (37%) Male: 19 (63%) Race/ethnicity (n [%]): NR - presume all native Japanese Baseline blood pressure: Supine pre-dialysis (only mean BP reported); measured using mercury sphygmomanometer Baseline mean BP (SD) reported for n = 30 completers: Losartan: 101.5 (4) Enalapril: 101.2 (3.3) Amlodipine: 99.3 (2.2) Concurrent medications (n [%]): NR Comorbidities (n [%]): Diabetes: Total - 12/30 (40%) Each group had 4/10 (40%) Recruitment setting: Single dialysis center in Osaka, Japan Inclusion criteria: - Uremia referred for dialysis - On maintenance dialysis for at least 1 mo - Maintained stable post-dialysis weight - SBP > 150 or DBP > 90 Exclusion criteria: - History of ischemic heart disease - History of CVA - Inadequate echocardiogram for LV mass - Atrial fibrillation - Recurrent CHF - Significant valvular heart disease - Nephritic syndrome - History of neoplasia | | | | | 1) Blood pressure: Mean BP, supine and pre-dialysis (seated values, supine SBP and DBP not reported); number analyzed is 10 per group: | | | | | General comments: See below Quality assessment: Overall rating: Fair Comments: - Small study - Single center - Number of patients randomized to various treatment groups NR - See comments immediately below, under Applicability Applicability: - Probably does not reflect equivalent doses of enalapril and losartan, biasing results in favor or losartan - Reports only mean arterial pressure (not SBP, DBP), so difficult to compare to other studies - Unique dialysis population; may not generalize to non-dialysis hypertensive patients
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | Baseline | 101.5 (4) | 101.2 (3.3) | 99.3 (2.2)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | 6 mo | 90.8 (2.5) | 90.1 (0.9) | 88.3 (1.7)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | P < 0.05 for all pre-post differences. No p-values reported for between-group differences. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: 1 death (treatment group not specified) 4) Morbidity: 1 MI (treatment group not specified) 5) Safety: 7 patients withdrawn from study and not included in analysis: - 1 had heart attack - 1 switched from hemo to peritoneal dialysis - 1 had myocarditis - 1 had death from pulmonary bleeding - 3 transferred to other hospitals No information on initial treatment arm for above withdrawals 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: Mean (SD) Left Ventricular Mass Index (g/m^2^):
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | Baseline | 154.5 (9.9) | 155.6 (14.3) | 156.6 (7.3)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | 6 mo | 114.6 (5.8) | 135.3 (10.4) | 137.2 (4.1)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | Change | -24.7 (3.2) | -11.2 (4.1) | -10.5 (5.2)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | P < 0.05 for all pre-post for losart and enalapril, but not amlodipine P< 0.05 for difference in losartan group compared to enalapril or amlodipine They also report measurements of interventricular septum, posterior wall, end- diastolic volume index, collapsibility index of IVC and LV ejection fraction 12) Creatinine/GFR: Mean (SD) serum Cr (mg/mL):
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | Baseline | 9.0 (0.4) | 9.9 (0.7) | 8.7 (0.5)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | 6 mo | 9.2 (0.5) | 10.2 (0.5) | 9.4 (0.9)
Shibasaki, Masaki, Nishiue, et al., 2002 #4460 | | | | | | | 13) Proteinuria: NR
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | Geographical location: 32 centers in Finland, Denmark, Iceland, and Norway Study dates: NR Funding source: NR Interventions: - Losartan 50 mg (n = 202) - Enalapril 20 mg (n = 205) No dose titration or co-interventions Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: Yes - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: NR - Eligible for inclusion: NR - Randomized: 407 - Began treatment: 399 - Completed treatment: 382 - Withdrawals/losses to followup: 25 Age: Cannot determine mean age; distribution for total sample: | | | | | 1) Blood pressure: N = 399 total for “all patients treated” analysis Mean (SD) seated trough SBP: | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - No description of recruiting strategy, allocation, or number of screened patients Applicability: - Racially homogeneous population (100% white) with very few comorbidities – does not represent general hypertension population - There were many protocol deviations in the timing of trough BP measurement resulting in a separate analysis (that was likely post-hoc)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | Age | N | % | | | | Losartan (n = 200) | Enalapril (n = 199)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | < 35 | 19 | 4.7 | | | Baseline | 157.5 (17.1) | 158.8 (16.5)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | 35–44 | 70 | 17.2 | | | 12 wk | 146.9 (18.3) | 146.0 (16.9)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | 45–54 | 152 | 37.3 | | | Change | -10.6 (13) | -12.9 (12.9)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | 55–64 | 110 | 27.0 | | | p < 0.01 for within-group pre-/post- changes p < 0.05 enalapril vs. losartan Mean (SD) seated trough DBP:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | > 64 | 56 | 13.8 | | | | Losartan (n = 200) | Enalapril (n = 199)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | Sex (n [%]): Female: 151 (37.1%) Male: 256 (62.9%) Race/ethnicity (n [%]): 100% white Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomano- meter after 10 min supine rest; average of 3 readings taken at 1-min intervals | | | | | Baseline | 103.1 (6.0) | 103.7 (6.1)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | [underlined: Losartan] | [underlined: Enalapril] | | | 12 wk | 94.7 (9.0) | 93.0 (7.9)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | SBP | 157.5 ±17.1 | 158.8 ± 16.5 | | | Change | -8.4 (7.1) | -10.6 (7.2)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | DBP | 103.1 ± 6.0 | 103.7 ± 6.1 | | | p < 0.01 for within-group pre-/post- changes p < 0.05 enalapril vs. losartan Also reported is a separate “per protocol” analysis that excluded patients who did not have BP measured at the appropriate trough time Also reported is the distribution of treatment response (defined as “excellent, good, fair, or poor”). These results also favored enalapril (p < 0.05). 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | Concurrent medications (n [%]): Patients discontinued other antihypertensive meds Comorbidities (n [%]): Not listed, but include category of “secondary diagnoses” (not defined) Secondary Diagnoses – “Yes”: Losartan: n = 123 (60.9%) Enalapril: n = 126 (61.5%) Total: n = 249 (61.2%) Recruitment setting: Outpatient primary care clinics Inclusion criteria: - Age 20–75 - Sitting DBP 95–120 after 2 wk of placebo Exclusion criteria: - Previous therapy of > 2 antihypertensive meds - Secondary hypertension - Renal impairment (Cr >150 μmol/L) - Proteinuria > 1+ on dipstick - CVA, TIA, or HTN encephalopathy in last 1 yr - MI or angina pectoris in last 6 months - Pregnant or nursing women - Women of child bearing potential - Current use of NSAIDs or corticosteroids or drugs known to affect BP - Uncontrolled DM (fasting BS > 11 mmol/L) - Obesity (arm circumference >41) - Serum potassium < 3.5 or > 5.5 - Abnormal liver function test (twice upper limit of normal) - Hgb level < 100g/dL - “Other clinically important disease that might interfere with participation” - Previous adverse reaction or lack of treatment response to ACEI | | | | | | Losart, n (%) | Enal, n (%) | p- value
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Total AEs | 65 (32.2%) | 93 (45.4%) | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Possibly drug-related AEs | 23 (11.4%) | 52 (25.4%) | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Withdrawals due to AEs | 6 (3%) | 14 (6.8%) | NS
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Withdrawals due to drug- related AEs | 3 (1.5%) | 12 (5.9%) | < 0.05
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 6) Specific adverse events: Headache, edema, rash/itching mentioned as AEs, but not quantified.
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losart | Enal | p-value
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Dry cough at 12 wk | 1% | 12.2% | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losartan (mean change %) | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Cholesterol level | 1.8 | -0.2
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | HDL cholesterol | 2.1 | 1.5
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Triglycerides | -3.0 | 2.3
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losartan (mean change %) | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Glucose level | -0.8 | 0
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losartan (mean change %) | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Creatinine level | -0.1 | 1.7
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 13) Proteinuria: Reported for subgroup of patients only (n = 93 Danish and Finnish patients) Urinary albumin/creatinine ratio (geometric mean x/- antilog SD) in total subgroup:
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losartan (n = 46) | Enalapril (n = 47)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Baseline | 1.14 x/−2.48 | 0.95 x/−2.45
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 12 wks | 0.81 x/−2.45 | 0.73 x/−2.0
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Differences are significant pre-/post- (p < 0.05), but not between treatments. Urinary albumin/creatinine ratio (geometric mean x/- antilog SD) in microalbuminuric patients (n = 23):
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | | Losartan (n = 12) | Enalapril (n = 11)
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Baseline | 4.16 x/− 1.73 | 3.62 x/− 1.69
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | 12 wks | 1.77 x/− 3.94 | 1.52 x/− 2.21
Tikkanen, Omvik, and Jensen, 1995 #7170 and Nielsen, Dollerup, Nielsen, et al., 1997 #12180 | | | | | | | Differences are significant pre-/posts (p < 0.05), but not between treatments.
Townsend, Haggert, Liss, et al., 1995 #7200 | Geographical location: Philadelphia, PA (31 centers) Study dates: NR Funding source: NR (one author from Merck) Interventions: - Losartan: 50 mg once daily switched after 8 weeks, if necessary, to 50 mg losartan plus 12.5 mg HCTZ (n = 132) - Enalapril: 5 mg once daily switched after 4 weeks, if necessary, to 10 mg enalapril and then to 10 mg enalapril and plus 25 mg HCTZ after 8 weeks (n = 136) Titration at each step was required if the SDP remained ≥ 90 mm. Early entry was possible if mean SDBP of 110–115 was evident at baseline and confirmed and confirmed at a repeat visit within 3 days Patients stratified by SDBP. Mild hypertension = mean SDBP 95- 104 Moderate =105–115 mm Study medication: Once a day between 6.30–9.30am. On the morning of clinic visits no medication until bp was measured: all measurements at end of 24-hr dosing interval Study design: RCT, parallel-group Blinding: - Patients: Yes - Providers: NR - Assessors of outcomes: Yes Each patient got an active and a placebo of the alternative treatment using a double blind double dummy design Was allocation concealment adequate?: NR Baseline/run-in period: 4 week placebo run-in (2 placebo tablets each day in the morning, 1 matching losartan and 1 matching enalapril) Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: - Eligible for inclusion: - Randomized: 268 - Began treatment: NR - Completed treatment: NR - Withdrawals/losses to followup: 31, 21 due to AEs, 10 due to protocol violations Age: Mean (SD): 54.5, 79.5% < 65 yr Median: NR Range: NR Sex (n [%]): Female: 136 (51%) Male: 132 (49%) Race/ethnicity (n [%]): Black: 65 (25%) White: 148 (63%) Hispanic: 26 (10%) Oriental: 5 (2%) Native American: 1 (0.5%) Other: 3 (0.5%) Baseline blood pressure: At each visit sitting SBP at trough at end of dosing interval and before administration of daily dose. BP measurements after 5 min of rest, in sitting position using a standard mercury sphygmomanometer. Readings repeated to obtain 3 consecutive readings within 1 min interval that did not vary by more than 5 mm from the calculated average of last 3 readings. Primary endpoint was change in mean sitting DBP from baseline to end of study Baseline SiDBP: Losartan: 101 ± 5 Enalapril: 100 ± 4 Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: Mean SDBP ≥ 95 and ≤ 115 mm, and did not vary by more than 7 mm between measurements Exclusion criteria: - Previously recd. ACE or ARBs - Sensitivity or intolerance to either drug - History of angioedema, heart failure, sec hypertension, malignant hypertension, hypertensive encephalopathy, hypertensive retinopathy, potentially life- threatening arrythmias, decompensated valvular disease, MI, angioplasty, recent coronary bypass surgery, cerebrovascular accident - Pregnant or breast-feeding women | | | | | 1) Blood pressure: At 12 wk, patients in the losartan group had a mean SBP reduction of 10.3 mm Hg vs. 9.8 mm Hg for enalapril (p = 0.31). 68% of patients taking losartan and 60% of patients taking enalapril reached goal BP (sitting DBP < 90 mm Hg or reduction ≥ 10 mm Hg in sitting DBP vs. baseline; p = 0.16). No other quantitative data reported for overall group results. Subgroup results: | | | | | General comments: - Study setting not described (“centers”) Quality assessment: Overall rating: Fair Comments: - No quantitative data reported for overall group results Applicability: - Sites not described
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | | Losart | Enal | p
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Black (n) | (33) | (32)
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 4 | −6.5 | −3.3 | 0.02
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 8 | −6.8 | −5.2 | 0.06
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 12 | −10.0 | −8.0 | 0.02
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Non-black (n) | (99) | (104)
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 4 | −8.4 | −7.0 | 0.10
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 8 | −9.6 | −9.2 | 0.47
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 12 | −10.4 | −10.4 | 0.51
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | ≥ 65 yr | (25) | (30)
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 4 | −9.0 | −6.4 | 0.06
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 8 | −9.6 | −8.4 | 0.17
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 12 | −12.7 | −10.1 | 0.03
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | < 65 yr | (107) | (68)
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 4 | −7.6 | −4.9 | 0.19
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 8 | −8.7 | −8.6 | 0.06
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | Wk 12 | −9.8 | −8.6 | 0.75
Townsend, Haggert, Liss, et al., 1995 #7200 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Of 132 losartan patients, 62 (47%) received 50 mg losartan alone, 70 (53%) received 50 mg losartan + 12.5 mg HCTZ by end of study. Of 130 enalapril patients: 33 (24%) received 5 mg enalapril, 39(29%) were titrated to and continued taking 10 mg enalapril, and 64(47%) received 10 mg enalapril + 25 mg HCTZ by end of study. Between-group differences were not statistically significant. 3) Mortality: NR 4) Morbidity: NR 5) Safety: No lab test AEs were serious, no ECG AEs were serious 66% of enalapril patients had 1 or more AE 55% of losartan patients had 1 or more AE 35/132 losartan patients (27%) and 36/136 enalapril patients (26%) had a drug-related AE; no patient had a serious drug-related AE No statistically significant difference in the number of patients who withdrew due to an AE (9 losartan vs. 12 enalapril) 6) Specific adverse events: Most common AEs (losartan, enalapril): Headache: 10%, 15% Cough: 7%, 12% URI: 8%, 10% Dizziness: 5%, 7% Asthenia: 6%, 2% Drug-related AEs (losartan, enalapril): Cough: 4%, 10% Headache: 4%, 4% Dizziness: 2%, 3% Asthenia/fatigue: 27%, 26% 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | Geographical location: Osaka, Japan Study dates: NR Funding source: NR Interventions: - Quinapril 10 mg (n = 25) - Losartan 50 mg (n = 18) Dose titration and co-interventions: If BP not controlled at 2 mo, then given combination of 2 study drugs (i.e., quinapril 10 mg + losartan 50 mg) Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: NR Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 1 yr Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 58 - Eligible for inclusion: NR - Randomized: 57 - Began treatment: 57 - Completed treatment: NR - Withdrawals/losses to followup: NR Age: Mean (SD): 61 ± 9 Median: NR Range: NR Sex (n [%]): Female: 32 (56%) Male: 25 (44%) Race/ethnicity (n [%]): NR, but presumably 100% Asian Baseline blood pressure: Trough seated BP measured 3 times at 2-min intervals with patient resting using an automatic sphygmomanometer; average of 2 “most stable” readings used Baseline values (mean ± SD): | | | | | 1) Blood pressure: Quinapril vs. losartan results reported only for patients who achieved response on monotherapy Mean BP (± SD) at 1 yr (monotherapy responders only): | | | | | General comments: - Quinapril vs. losartan results reported only for patients who achieved response on monotherapy - Open-label study allowing for bias in assessment Quality assessment: Overall rating: Fair Comments: - Recruitment and randomization not clearly described - Open-label study allowing for bias in assessment of outcomes - No data on safety/AEs or withdrawals Applicability: - Study location in single Japanese medical center - No reporting on safety/AEs/withdrawals - Quinapril vs. losartan results reported only for patients who achieved response on monotherapy
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | Quinapril alone (n = 25) | Losartan alone (n = 18) | | | | Quinapril alone (n = 25) | Losartan alone (n = 18)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | SBP | 156 ± 14 | 156 ± 12 | | | SBP | 136 ± 7 | 135 ± 6
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | DBP | 92 ± 9 | 92 ± 10 | | | DBP | 78 ± 7 | 76 ± 8
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | Concurrent medications (n [%]):NR Comorbidities (n [%]; n = 43 monotherapy responders): History of smoking: 17 (39.5%) History of diabetes: 11 (26%) History of hyperlipidemia: (37%) Recruitment setting: Outpatients attending renal and hypertension center at the university medical center Inclusion criteria: - Untreated hypertension - Diagnosed at the renal and htn center - Mild-to-moderate essential hypertension accord to Japanese Society of Hypertension guidelines Exclusion criteria: - Signs, symptoms, or history of cardiac or renal disease, cerebrovascular accident, or any major disease - Required anti-platelet or anti- coagulation medications | | | | | No significant difference between groups (p-value NR) 2) Rate of use of a single antihypertensive agent for BP control: 14/57 (25%) took combination quinapril and losartan due to inadequate BP control at 2 mo. Remainder (43/57 = 75%) stayed on monotherapy. 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels:
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | | Quinapril mono- therapy (n = 25) | Lisinopril mono- therapy (n = 18)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | LDL baseline | 134 (43) | 121 (27)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | LDL 1 yr | 126 (27) | 117 (31)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | HDL baseline | 56 (19) | 49 (13)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | HDL 1 yr | 59 (20) | 52 (16)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | TG baseline | 147 (56) | 156 (73)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | TG 1 yr | 150 (69) | 169 (55)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | None of the changes was statistically significant but no p-values reported Note: Patients taking antihyperlipidemia were not excluded, so cannot necessarily attribute lipid changes to study drugs 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control:
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | | Quinapril monotherapy (n = 25) | Lisinopril monotherapy (n = 18)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | HgA1c baseline | 5.5 (1.2) | 5.4 (1.1)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | HgA1c 1 yr | 5.4 (1.0) | 5.3 (1.5)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | None of the changes was statistically significant but no p-values reported Note: Patients taking antidiabetes drugs were not excluded 11) LV mass/function: NR 12) Creatinine/GFR:
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | | Quinapril monotherapy (n = 25) | Lisinopril monotherapy (n = 18)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | Cr baseline | 0.6 (0.2) | 0.7 (0.3)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | Cr 1 yr | 0.7 (0.3) | 0.7 (0.2)
Uchiyama- Tanaka, Mori, Kishimoto, et al., 2005 #1120 | | | | | | | Cr reported in mg/dL None of the changes was statistically significant but no p-values reported 13) Proteinuria: NR
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | Geographical location: Perugia, Italy Study dates: NR Funding source: Supported in part by grants from the associzone umbra cuore e lapertensione, perugia, italy Interventions: - Losartan 50 mg daily (n = 22) - Enalapril 20mg daily (n = 66) Dose titration/cointerventions: In both groups, HCTZ 25 mg daily added if needed (SBP ≥ 140 or DBP > 90) Study design: Case-control selected from observational registry (n = 701) Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: No randomization Baseline/run-in period: NA Duration of treatment: Average of 3.3 yr Duration of post-treatment followup: NA | Number of patients: - Screened for inclusion: 701 (from cohort) - Eligible for inclusion: NR - Randomized: NA - Began treatment: 108 - Completed treatment: 88 - Withdrawals/losses to followup: 20 (14 due to AEs, 6 for unspecified reasons) Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: 50% Male: 50% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough office BP assessed using a standard mercury sphygmanometer; mean of 3 measurements taken after subject rested for 10 min | | | | | 1) Blood pressure: Mean trough seated BP on treatment (avg. 3.3 yr): | | | | | General comments: - Baseline characteristics of patients NR Quality assessment: Overall rating: Poor Comments: - No baseline characteristics reported - No detail about extent of followup (only give average of 3.3 yr) Applicability: - No baseline patient characteristics described or compared - Little detail about selection of case- controls, reasons for exclusion from eligible patients - Duration of therapy not defined at all
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | [underlined: Losartan] | [underlined: Enalapril] | | | | [underlined: Losartan] | [underlined: Enalapril]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | SBP | 155 ± 14 | 155 ± 15 | | | SBP | 140 ± 14 | 140 ± 18
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | DBP | 100 ± 9 | 99 ± 9 | | | DBP | 90 ± 8 | 87 ± 7
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: <βρ><εεβ></εεβ> - from PIUMA (Progetto Ipertensione Umbria Monitoaggio Ambulatoriale) study [ref 4, 14 in paper] Inclusion criteria: - Office SBP ≥ 140 and/or DBP ≥ 90 on ≥ 3 visits - ≥ 1 valid BP measurement within 24h before enrollment Exclusion criteria: - Previous antihypertensive therapy or drugs withdrawn from ≥ 4 wk - Evidence of CHF, CAD, significant valvular defects - Secondary causes of HTN - “Other concomitant important disease” | | | | | All pre-/post- differences p < 0.01 Between-group p-values NR Also report 24-hr ABPM data 2) Rate of use of a single antihypertensive agent for BP control: Number of patients (%) not taking adjunctive HCTZ: Losartan: 12 (55%) Enalapril: 32 (48%) 3) Mortality: NR 4) Morbidity: NR 5) Safety: Withdrawals due to AEs: Losartan: 2 (headache, gastric distress) Enalapril: 12 (all cough) 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean total cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 5.09 ± 0.79 | 5.23 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 5.51 ± 0.93 | 5.92 ± 0.92 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Mean HDL cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 1.26 ± 0.30 | 1.30 ± 0.21 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 1.24 ± 0.28 | 1.28 ± 0.32 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Mean LDL cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 3.42 ± 0.79 | 3.32 ± 0.82 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 3.59 ± 0.85 | 3.77 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Mean triglycerides (mmol/L): | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 1.23 ± 0.49 | 1.34 ± 0.56 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 1.47 ± 0.78 | 1.78 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean glucose (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 5.36 ± 0.65 | 5.31 ± 0.61 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 5.56 ± 0.88 | 5.61 ± 0.90 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | 11) LV mass/function: LV mass (g/BSA [m^2^]):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 98 ± 18 | 87 ± 19 | <0.001
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 98 ± 20 | 89 ± 20 | <0.001
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Similar results with LV mass in g/height Also report multiple other echo measurements including - IVS thickness, LV internal diam, PW thickness, endocardial shortening fraction, midwall shortening fraction, peak E/A ratio 12) Creatinine/GFR: Mean creatinine (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Losartan | 85.7 ± 10.4 | 83.9 ± 12.9 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Enalapril | 82.8 ± 14.7 | 93.2 ± 75.6 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #5560 | | | | | | | Note - SD for enalapril on f/u must be a typo 13) Proteinuria: NR
Williams, Gosse, Lowe, et al., 2006 #340 | Geographical location: 75 centers Austria, France, Germany, Netherlands, South Africa, Spain, Switzerland, and United Kingdom Study dates: NR Funding source: NR Interventions: - Telmisartan 40 mg initial dose and forced titration to 80 mg after 2 wk (n = 397) - Ramipril 5 mg for 8 wk and then force titrated to ramipril 10 mg for the last 6 wk (n = 404) Study design: RCT, parallel-group Blinding: - Patients: No - Providers: No - Assessors of outcomes: Yes Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 4-wk single-blind placebo run-in phase in which prior antihypertensives were discontinued Duration of treatment: 14 wk Duration of post-treatment followup: NR | Number of patients: - Screened for inclusion: 1593 - Eligible for inclusion: 801 - Randomized: 801 - Began treatment: 801 - Completed treatment: 714 - Withdrawals/losses to followup: 57, 37 due to AEs, 10 due to lack of efficacy, 10 withdrew consent (note: reported numbers do not total correctly) Age: Mean (SD): 53.6 (10.6) Median: NR Range: NR Sex (n [%]): Female: 322 (41.2%) Male: 479 (59.8) Race/ethnicity (n [%]): White 621 (77.5%) Black 14 (1.7%) Mongoloid 7 (0.9%) Missing 159 (19.9%) Baseline blood pressure: Seated trough BP measured in triplicate using a manual sphygmomanometer according to ASH guidelines | | | | | 1) Blood pressure: Changes in trough seated BP from baseline to 14 wk: Reductions were greater with telmisartan 80 mg than with ramipril 10 mg by 4.6 mm Hg for SBP (p < 0.0001) and by 2.2 mm Hg for DBP (p = 0.0002). Pre-/post-treatment mean values NR. Seated DBP response (DBP < 90 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 61.9% Ramipril: 54.8% (p = 0.03) Seated SBP response (SBP < 140 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 76.2% Ramipril: 66.9% (p = 0.004) Also report BP in last 6 hours of 24 hours of ABPM 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: There were no deaths during the study. 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 153/397 (38.5%) Ramipril: 162/404 (40.1%) Severe AEs: Telmisartan: 13 (3.3%) Ramipril: 17 (4.2%) Drug-related AEs: Telmisartan: 6.5% Ramipril: 10.1% Drug-related serious AEs: 0 6) Specific adverse events: Drug-related AEs with incidence greater than 1% (fatigue, dizziness, HA, and cough) occurred in 14 (3.5%) telmisartan vs. 23 (5.7%) ramipril patients Cough: 2 (0.5%) telmisartan vs. 23 (5.7%) ramipril 7) Persistence/adherence: Compliance with treatment was high (> 98.8%) in both groups – recognize this is in 714/801 patients that completed study 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | General comments: - Titrations at different times so that telmisartan is titrated up and to higher relative dose than ramipril - No discussion outside of forced titration of BP checks during study and if any additional agents or if SBP very high what was done Quality assessment: Overall rating: Fair Comments: - No clear concealment of randomization - Not blinded - Titrated drugs at different times Applicability: Excludes so many patients that patients with heart disease, or patients with many comorbidities would be excluded from the trial
Williams, Gosse, Lowe, et al., 2006 #340 | | | [underlined: Telmisartan] | [underlined: Ramipril]
Williams, Gosse, Lowe, et al., 2006 #340 | | SPB | 158.5 ± 11.9 | 158.3 ± 12.5
Williams, Gosse, Lowe, et al., 2006 #340 | | DBP | 100.1 ± 4.9 | 100.1 ± 4.9
Williams, Gosse, Lowe, et al., 2006 #340 | | Concurrent medications (n [%]):NR Comorbidities (n [%]): NR Recruitment setting: Clinic setting Inclusion criteria: - Mean seated DBP of 95–109 mm Hg measured using a manual sphygmomanometer (mean of 3 measurements taken 2 min apart) - 24-hr ABP of DBP ≥ 85 mm Hg after run-in period Exclusion criteria: - Known or suspected history of coronary disease, stroke, congestive heart failure, or recent acute cardiovascular event, secondary hypertension, poorly controlled insulin-dependant diabetes mellitus, or chronic kidney disease - Premenopausal women not using adequate contraception - Night shift workers
Wogen, Kreilick, Livornese, et al., 2003 #12890 | Geographical location: U.S. (“geographically diverse” claims database) Study dates: Aug 1998 – Jul 2000 Funding source: Novartis Pharmaceuticals, Inc. Interventions: Lisinopril (n = 40,238) Valsartan (n = 29,669) Amlodipine (n = 73,148) Study design: Retrospective cohort study Blinding: - Patients: No - Providers: No - Assessors of outcomes: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 1 yr | Number of patients: - Screened for inclusion: 14.6 million - Eligible for inclusion: 142,945 - Randomized: NA - Began treatment: 142,945 - Completed treatment: NA - Withdrawals/losses to followup: NA Age: Mean (SD): 63.1 (14.0) Median: NR Range: NR Sex (n [%]): Female: 53% Male: 47% Race/ethnicity (n [%]): NR; database stated to be “demographically diverse” Baseline blood pressure: NR Concurrent medications (n [%]): Concurrent cardiovascular meds: Diuretics: 35% Antihyperlipidemics: 32% Beta-blockers: 25.5% Antiplatelets: 14% Nitrates: 15% Digitalis: 9% Diuretic combination: 8% Valsartan patients significantly less likely to be prescribed these meds than patients in other two groups. Comorbidities (n [%]): Mean Chronic Disease Score (± SD) was 10.15 ± 6.00 for the entire cohort and was essentially comparable for all groups A significantly smaller proportion of valsartan patients was classified as having a “severe” chronic disease burden (35% vs. 31% for both lisinopril and amlodipine; p < 0.0001) Recruitment setting: Administrative pharmacy claims database from a large pharmacy benefits manager. Described as a “demographically and geographically diverse database that contains 3 years of longitudinal pharmacy claims data representing the payer mix in the U.S. health care market, including drug-insured lives from health care insurance carriers, managed care organizations, employers, and retirement and government plans.” Inclusion criteria: - Continuously benefit-eligible for both mail-order and community pharmacy prescriptions between 1 Aug 1997 and 31 Jul 2000 - Initial prescription for one of 3 study drugs between 1 Aug 1998 and 31 Jul 1999 - New to therapy within the drug class (patients who received a prescription for a drug from the same class in the preceding 12 mo were excluded) Exclusion criteria: None specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Discontinuation was defined as a 60+ day period without a new prescription; persistence was defined as the absence of discontinuation. Discontinuation was examined directly and also in a Cox model that controlled for age, sex, chronic disease burden, and use of other antihypertensive agents. The results of this modeling were similar to the unadjusted results. Compliance was not measured directly, but instead was estimated as the total days’ supply of all prescriptions divided by the length of therapy. Predictors of non-compliance included older age, female sex, high chronic disease scores, use of lipid medications, use of beta-blockers, and use of nitrates. | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: - Non-random allocation to drugs - Differences noted in comorbidity between valsartan-treated patients and those on other antihypertensive drugs - Funded by pharmaceutical company Applicability: - Study period soon after introduction of ARBs; early use may not reflect current use patters
Wogen, Kreilick, Livornese, et al., 2003 #12890 | | | | | | | | [underlined: 1-yr persistence] | [underlined: Compliance]
Wogen, Kreilick, Livornese, et al., 2003 #12890 | | | | | | | Lisinopril | 50% | 86.3%
Wogen, Kreilick, Livornese, et al., 2003 #12890 | | | | | | | Valsartan | 63% | 88.5%
Wogen, Kreilick, Livornese, et al., 2003 #12890 | | | | | | | Amlodipine | 53% | 86.7%
Wogen, Kreilick, Livornese, et al., 2003 #12890 | | | | | | | 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR