# Abstract and Full-Text Screening Criteria

## Abstract Screening Instructions

An abstract will be [underlined: included] if any of the following criteria apply:

- The study is a [underlined: direct comparison] (any study design) of an ACEI versus an ARB (see list below; additional antihypertensive therapy OK if the same in both groups);
- The study is an [underlined: indirect comparison] (RCT only) of either an ACEI or an ARB (see list below) versus another antihypertensive or placebo (additional antihypertensive therapy OK if the same in all groups);
- The study is an [underlined: indirect comparison] (RCT only) of a combination of an ACEI or an ARB (see list below) plus another antihypertensive versus another antihypertensive or placebo;
- Original data.

An abstract will be [underlined: excluded] if any of the following criteria apply:

- No patients have hypertension OR some patients have hypertension, but results not reported separately for this subgroup;
- All subjects aged < 18 years OR some subjects aged < 18 years, but results not broken down by age;
- Dose comparison studies with no placebo arm;
- Only comparison is an ACEI + an ARB versus placebo.

An abstract will be identified as a [underlined: review] if it is a relevant review article, meta-analysis, methods article, or cost-effectiveness analysis.

For each abstract, please mark either “EX” for [underlined: Exclude], “IN” for [underlined: Include] or “R” for [underlined: Review].

For included studies, please mark:

- “AVA” if the study is a [underlined: direct comparison] of an ACEI versus an ARB;

- “AVO” if the study is an [underlined: indirect comparison] of either (1) an ACEI or an ARB versus some other antihypertensive or placebo OR (2) a combination of an ACEI or an ARB plus another antihypertensive versus an antihypertensive or placebo.

For all included studies, please also indicate the [underlined: longest length (weeks or months) of followup].

Thus, coding for each abstract should be either:

- - EX
- - R
- - IN AVA (specify # weeks or # months follow-up, or write “NS” if length of follow-up not specified)
- - IN AVO (specify # weeks or # months follow-up, or write “NS”)

[underlined: Included ACEIs]

- benazepril (Lotensin)
- captopril (Capoten)
- enalapril (Vasotec; Enalaprilat IV)
- fosinopril (Monopril)
- lisinopril (Prinivil, Zestril)
- moexipril (Univasc)
- perindopril (Aceon)
- quinapril (Accupril)
- ramipril (Altace)
- trandolapril (Mavik)

[underlined: Included ARBs]

- candesartan cilexetil (Atacand)
- eprosartan (Teveten)
- irbesartan (Avapro)
- losartan (Cozaar)
- olmesartan medoxomil (Benicar)
- telmisartan (Micardis)
- valsartan (Diovan)

## Direct ACEIs vs. ARBs Comparisons – Full-Text Screening Criteria

Note: Articles coded at the abstract screening stage as included, but having a treatment duration/followup lasting < 12 weeks (n = 88), were excluded at this stage without further review. The remaining 103 included abstracts with treatment duration/followup ≥ 12 weeks were reviewed in full-text form. Screeners were instructed to work from top to bottom of the following list, choosing the first (if any) exclusion reason that applied.

1) Condition of interest = essential hypertension

- - Exclude if no patients have essential hypertension or if results not reported separately for subgroup with essential hypertension

2) Population of interest = adults (≥18 years)

- - Exclude if all subjects < 18 or if results not reported separately for ≥18 subgroup

3) Interventions & comparators of interest:

[underlined: ACEIS]

- benazepril (Lotensin)
- captopril (Capoten)
- enalapril (Vasotec; Enalaprilat IV)
- fosinopril (Monopril)
- lisinopril (Prinivil, Zestril)
- moexipril (Univasc)
- perindopril (Aceon)
- quinapril (Accupril)
- ramipril (Altace)
- trandolapril (Mavik)

[underlined: ARBS]

- candesartan cilexetil (Atacand)
- eprosartan (Teveten)
- irbesartan (Avapro),
- losartan (Cozaar)
- olmesartan medoxomil (Benicar)
- telmisartan (Micardis)
- valsartan (Diovan)

- - Include “grouped” comparisons, e.g., specific ARB vs. “ACE inhibitors” or unspecified “ARBs” vs. unspecified “ACEIs”
- - Include ACEI + drug X vs. ARB + drug X (e.g., losartan + HCTZ vs. enalapril + HCTZ)
- - Exclude ACEI + drug X vs. ARB + drug Y (e.g., enalapril + manidipine vs. irbesartan + HCTZ)
- - Exclude if ACEI or ARB not on above list

4) Study designs:

- - Include all clinical study designs (RCTs, non-RCTs, cohorts, etc.); cross-sectional studies OK if time on treatment reported and ≥12 weeks
- - Exclude if not clinical study (review, etc. – please specify)

5) Outcomes of interest:

For Key Question 1:

- Intermediate outcomes:
  - Blood pressure control
  - Rate of use of a single antihypertensive agent for blood pressure control
  - Lipid levels
  - Progression to type 2 diabetes
  - Markers of carbohydrate metabolism/diabetes control (glycated hemoglobin [HbA1c], dosage of insulin or other diabetes medication, fasting plasma glucose, aggregated measures of serial glucose measurements)
  - LV mass/function
  - Creatinine/GFR
  - Proteinuria
- Health outcomes:
  - Mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific)
  - Morbidity (cardiac events [MI], heart failure, cerebral vascular disease or events [including stroke], symptomatic coronary artery disease, end-stage renal disease, PVD [as clinically manifest, not markers of], quality of life)

For Key Question 2:

- Safety (overall adverse events, withdrawals due to adverse events, serious adverse events reported, withdrawal rates, switch rates)
- Specific adverse events (including, but not limited to: weight gain, impaired renal function, angioedema, cough)
- Tolerability
- Persistence
- Adherence

6) Sample size:

- - Exclude if total number of patients randomized to ACEI and ARB treatment arms < 20

7) Treatment duration/length of followup:

- - Exclude if treatment duration or longest followup < 12 weeks