# Exact Search Strings

MEDLINE ^®^ Search 1: Used to identify studies of (a) ACEIs vs. ARBs and (b) ARBs vs. other (non-ACEI) comparators. ACEIs vs. ARBs portion of strategy also used to search the Cochrane Central Register of Controlled Trials.

Database: Ovid MEDLINE^®^ <1966 to May Week 3 2006>
Search Strategy:
1 | (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7801)
2 | losartan/(3821)
3 | angiotensin II type 1 receptor blockers/(1417)
4 | (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (89)
5 | or/1–4 (8186)
6 | (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20419)
7 | angiotensin-converting enzyme inhibitors/or captopril/or cilazapril/or enalapril/or enalaprilat/or fosinopril/or lisinopril/or perindopril/or ramipril/(29181)
8 | 6 or 7 (31620)
9 | 5 and 8 (2561)
10 | limit 9 to yr="1989 – 2006" (2561)
11 | limit 10 to humans (1570)
12 | limit 11 to english language (1302)
13 | exp hypertension/dt (43028)
14 | 12 and 13 (501)
15 | randomized controlled trial.pt. (225487)
16 | controlled clinical trial.pt. (73200)
17 | Randomized Controlled Trials/(45397)
18 | Random Allocation/(57318)
19 | Double-Blind Method/(88071)
20 | Single-Blind Method/(10138)
21 | or/15–20 (382640)
22 | Animal/not Human/(3011569)
23 | 21 not 22 (360978)
24 | clinical trial.pt. (447512)
25 | exp Clinical Trials/(188054)
26 | (clinic$ adj25 trial$).tw. (122637)
27 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84242)
28 | Placebos/(25150)
29 | placebo$.tw. (97000)
30 | random$.tw. (351176)
31 | Research Design/(44423)
32 | (latin adj square).tw. (2271)
33 | or/24–32 (817761)
34 | 33 not 22 (760307)
35 | 34 not 23 (412905)
36 | Comparative Study/(1296809)
37 | exp Evaluation Studies/(574715)
38 | Follow-Up Studies/(327165)
39 | Prospective Studies/(209742)
40 | (control$ or prospectiv$ or volunteer$).tw. (1678468)
41 | Cross-Over Studies/(18169)
42 | or/36–41 (3339392)
43 | 42 not 22 (2575440)
44 | 43 not (23 or 35) (2038591)
45 | 23 or 35 or 44 (2812474)
46 | 14 and 45 (421)
47 | limit 46 to abstracts (383)
48 | 46 not 47 (38)
49 | 5 and 13 and 23 (812)
50 | 5 and 13 and 15 (577)
51 | limit 50 to humans (576)
52 | limit 51 to english language (547)
53 | limit 52 to abstracts (526)
54 | 53 not 47 (355)
55 | 47 or 54 (738)
56 | from 55 keep 1–738 (738)

MEDLINE ^®^ Search 2: Used to identify studies of ACEIs vs. atenolol or amlodipine.

Database: Ovid MEDLINE^®^ <1966 to June Week 2 2006>
Search Strategy:
1 | (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7907)
2 | losartan/(3866)
3 | angiotensin II type 1 receptor blockers/(1495)
4 | (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (89)
5 | or/1–4 (8317)
6 | (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20515)
7 | angiotensin-converting enzyme inhibitors/or captopril/or cilazapril/or enalapril/or enalaprilat/or fosinopril/or lisinopril/or perindopril/or ramipril/(29405)
8 | 6 or 7 (31862)
9 | 5 and 8 (2616)
10 | limit 9 to yr="1989 – 2006" (2616)
11 | limit 10 to humans (1616)
12 | limit 11 to english language (1344)
13 | exp hypertension/dt (43234)
14 | 12 and 13 (513)
15 | randomized controlled trial.pt. (227233)
16 | controlled clinical trial.pt. (73582)
17 | Randomized Controlled Trials/(46059)
18 | Random Allocation/(57572)
19 | Double-Blind Method/(88623)
20 | Single-Blind Method/(10243)
21 | or/15–20 (385737)
22 | Animal/not Human/(3039204)
23 | 21 not 22 (363780)
24 | clinical trial.pt. (449329)
25 | exp Clinical Trials/(189510)
26 | (clinic$ adj25 trial$).tw. (124237)
27 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84782)
28 | Placebos/(25242)
29 | placebo$.tw. (97782)
30 | random$.tw. (355789)
31 | Research Design/(44740)
32 | (latin adj square).tw. (2283)
33 | or/24–32 (825939)
34 | 33 not 22 (767683)
35 | 34 not 23 (417884)
36 | Comparative Study/(1313583)
37 | exp Evaluation Studies/(581443)
38 | Follow-Up Studies/(330247)
39 | Prospective Studies/(211855)
40 | (control$ or prospectiv$ or volunteer$).tw. (1701806)
41 | Cross-Over Studies/(18356)
42 | or/36–41 (3382854)
43 | 42 not 22 (2610193)
44 | 43 not (23 or 35) (2068318)
45 | 23 or 35 or 44 (2849982)
46 | 14 and 45 (430)
47 | limit 46 to abstracts (392)
48 | 46 not 47 (38)
49 | 5 and 13 and 23 (826)
50 | 5 and 13 and 15 (589)
51 | limit 50 to humans (588)
52 | limit 51 to english language (559)
53 | limit 52 to abstracts (538)
54 | 53 not 47 (363)
55 | 47 or 54 (755)
56 | 8 and 13 and 45 (5143)
57 | amlodipine.mp. or Amlodipine/(2102)
58 | atenolol.mp. or Atenolol/(5762)
59 | 57 or 58 (7736)
60 | 8 and 59 (1120)
61 | 60 and 13 (767)
62 | 61 and 45 (678)
63 | 61 and 23 (501)
64 | 61 and 15 (388)
65 | limit 64 to humans (388)
66 | limit 65 to english language (369)
67 | limit 66 to abstracts (354)
68 | from 67 keep 1–354 (354)

MEDLINE ^®^ Search 3: Used to identify studies of ACEIs vs. placebo published after the June 2005 Drug Class Review on Angiotensin Converting Enzyme Inhibitors.^*^

* Chou R, Helfand M, Carson S. Drug Class Review on Angiotensin Converting Enzyme Inhibitors. Final Report. June 2005. Available at: www.ohsu.edu/drugeffectiveness/reports/final.cfm. Accessed 17 August 2006.

Database: Ovid MEDLINE^®^ <1966 to June Week 4 2006>
Search Strategy:
1 | (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7931)
2 | losartan/(3878)
3 | angiotensin II type 1 receptor blockers/(1523)
4 | (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (90)
5 | or/1–4 (8352)
6 | (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20553)
7 | angiotensin-converting enzyme inhibitors/or captopril/or cilazapril/or enalapril/or enalaprilat/or fosinopril/or lisinopril/or perindopril/or ramipril/(29480)
8 | 6 or 7 (31944)
9 | 5 and 8 (2631)
10 | limit 9 to yr="1989 – 2006" (2631)
11 | limit 10 to humans (1629)
12 | limit 11 to english language (1356)
13 | exp hypertension/dt (43305)
14 | 12 and 13 (516)
15 | randomized controlled trial.pt. (227810)
16 | controlled clinical trial.pt. (73653)
17 | Randomized Controlled Trials/(46324)
18 | Random Allocation/(57680)
19 | Double-Blind Method/(88793)
20 | Single-Blind Method/(10281)
21 | or/15–20 (386780)
22 | Animal/not Human/(3043394)
23 | 21 not 22 (364697)
24 | clinical trial.pt. (449647)
25 | exp Clinical Trials/(190053)
26 | (clinic$ adj25 trial$).tw. (124749)
27 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84961)
28 | Placebos/(25278)
29 | placebo$.tw. (98008)
30 | random$.tw. (356966)
31 | Research Design/(44861)
32 | (latin adj square).tw. (2289)
33 | or/24–32 (828165)
34 | 33 not 22 (769721)
35 | 34 not 23 (419156)
36 | Comparative Study/(1316751)
37 | exp Evaluation Studies/(582995)
38 | Follow-Up Studies/(331073)
39 | Prospective Studies/(212521)
40 | (control$ or prospectiv$ or volunteer$).tw. (1706292)
41 | Cross-Over Studies/(18430)
42 | or/36–41 (3391311)
43 | 42 not 22 (2617037)
44 | 43 not (23 or 35) (2073600)
45 | 23 or 35 or 44 (2857453)
46 | 14 and 45 (432)
47 | limit 46 to abstracts (393)
48 | 46 not 47 (39)
49 | 5 and 13 and 23 (829)
50 | 5 and 13 and 15 (590)
51 | limit 50 to humans (589)
52 | limit 51 to english language (560)
53 | limit 52 to abstracts (539)
54 | 53 not 47 (364)
55 | 47 or 54 (757)
56 | 8 and 13 and 45 (5155)
57 | amlodipine.mp. or Amlodipine/(2108)
58 | atenolol.mp. or Atenolol/(5772)
59 | 57 or 58 (7752)
60 | 8 and 59 (1123)
61 | 60 and 13 (768)
62 | 61 and 45 (679)
63 | 61 and 23 (502)
64 | 61 and 15 (389)
65 | limit 64 to humans (389)
66 | limit 65 to english language (370)
67 | limit 66 to abstracts (355)
68 | from 67 keep 1–354 (354)
69 | 56 and (28 or 29) (1286)
70 | limit 69 to humans (1286)
71 | limit 70 to english language (1154)
72 | limit 71 to abstracts (1150)
73 | (2005$ or 2006$).ed. (974282)
74 | 72 and 73 (52)
75 | from 74 keep 1–52 (52)