# References

1 DeVault KR, Castell DO. American College of Gastroenterology. Updated guidelines for the diagnosis and treatment of gastroesophageal reflux disease. American Journal of Gastroenterology. 2005;100(1):190-200. [pmid: 15654800].
2 Dent J, El Serag HB, Wallander MA, Johansson S. Epidemiology of gastro-oesophageal reflux disease: a systematic review. Gut. 2005;54(5):710-717. [pmid: 15831922]. [pmcid: 1774487].
3 Goodman C, Cronin K, Gemmen E et al. The Burden of Gastronintestinal Diseases. 2001. Bethsda, MD, American Gastroenterological Association.
4 Numans ME, Lau J, de Wit NJ, Bonis PA. Short-term treatment with proton-pump inhibitors as a test for gastroesophageal reflux disease: a meta-analysis of diagnostic test characteristics.[see comment]. Annals of Internal Medicine. 2004;140(7):518-27. [pmid: 15068979].
5 Chey WD, Inadomi JM, Booher AM, et al. Primary-care physicians' perceptions and practices on the management of GERD: Results of a national survey. Am J Gastroenterol. 2005;100(6):1237-1242. [pmid: 15929751].
6 Deviere J, Costamagna G, Neuhaus H, et al. Nonresorbable copolymer implantation for gastroesophageal reflux disease: a randomized sham-controlled multicenter trial.[see comment]. Gastroenterology. 2005;128(3):532-40. [pmid: 15765387].
7 Corley DA, Katz P, Wo JM, et al. Improvement of gastroesophageal reflux symptoms after radiofrequency energy: a randomized, sham-controlled trial.[see comment]. Gastroenterology. 2003;125(3):668-76. [pmid: 12949712].
8 Spechler SJ, Lee E, Ahnen D, et al. Long-term outcome of medical and surgical therapies for gastroesophageal reflux disease: follow-up of a randomized controlled trial.[see comment]. JAMA. 2001;285(18):2331-8. [pmid: 11343480].
9 Dial S, Alrasadi K, Manoukian C, Huang A, Menzies D. Risk of Clostridium difficile diarrhea among hospital inpatients prescribed proton pump inhibitors: cohort and case-control studies.[see comment]. CMAJ. 2004;171(1):33-8. [pmid: 15238493]. [pmcid: 437681].
10 Neal KR, Scott HM, Slack RC, Logan RF. Omeprazole as a risk factor for campylobacter gastroenteritis: case-control study. BMJ. 1996;312(7028):414-5. [pmid: 8601113]. [pmcid: 2350063].
11 Laheij RJ, Sturkenboom MC, Hassing RJ, et al. Risk of community-acquired pneumonia and use of gastric acid-suppressive drugs.[see comment]. JAMA. 2004;292(16):1955-60. [pmid: 15507580].
12 Freston JW. Omeprazole, hypergastrinemia, and gastric carcinoid tumors.[see comment][comment]. Annals of Internal Medicine. 1994;121(3):232-3. [pmid: 8017751].
13 Kuipers EJ, Lundell L, KlinkenbergKnol EC, et al. Atrophic gastritis and Helicobacter pylori infection in patients with reflux esophagitis treated with omeprazole or fundoplication.[see comment]. New England Journal of Medicine. 1996;334(16):1018-22. [pmid: 8598839].
14 Lundell L, Miettinen P, Myrvold HE, et al. Lack of effect of acid suppression therapy on gastric atrophy. Nordic Gerd Study Group.[see comment]. Gastroenterology. 1999;117(2):319-26. [pmid: 10419912].
15 Streets CG, DeMeester TR. Ambulatory 24-hour esophageal pH monitoring: why, when, and what to do.[see comment]. [Review] [30 refs]. Journal of Clinical Gastroenterology. 2003;37(1):14-22. [pmid: 12811203].
16 U.S.Food and Drug Administration, http://www.fda.gov/cdrh/maude.html. Manufacturer and User Facility Device experience Database - (MAUDE). Internet website. 2005.
17 Moher D, Cook DJ. Eastwood S et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses.[see comment]. [Review] [49 refs]. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
18 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration.[see comment]. [Review] [204 refs]. Annals of Internal Medicine. 2001;134(8):663-94. [pmid: 11304107].
19 Moher D, Schulz KF, Altman D. CONSORT GROUP (Consolidated Standards of Reporting Trials). The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials.[see comment]. [Review] [30 refs]. JAMA. 2001;285(15):1987-91. [pmid: 11308435].
20 Behar J, Sheahan DG, Biancani P, Spiro HM, Storer EH. Medical and surgical management of reflux esophagitis. A 38-month report of a prospective clinical trial. New England Journal of Medicine. 1975;293(6):263-8. [pmid: 237234].
21 Lundell L, Miettinen P, Myrvold HE, et al. Long-term management of gastro-oesophageal reflux disease with omeprazole or open antireflux surgery: results of a prospective, randomized clinical trial. The Nordic GORD Study Group.[see comment]. European Journal of Gastroenterology & Hepatology. 2000;12(8):879-87. [pmid: 10958215].
22 Lundell L, Miettinen P, Myrvold HE et al. Continued (5-year) followup of a randomized clinical study comparing antireflux surgery and omeprazole in gastroesophageal reflux disease.[see comment]. Journal of the American College of Surgeons 2001;discussion-81.
23 Mahon D, Rhodes M, Decadt B, et al. Randomized clinical trial of laparoscopic Nissen fundoplication compared with proton-pump inhibitors for treatment of chronic gastro-oesophageal reflux. British Journal of Surgery. 2005;92(6):695-9. [pmid: 15898130].
24 Spechler SJ. Comparison of medical and surgical therapy for complicated gastroesophageal reflux disease in veterans. The Department of Veterans Affairs Gastroesophageal Reflux Disease Study Group.[see comment]. New England Journal of Medicine. 1992;326(12):786-92. [pmid: 1538721].
25 Fernando HC, Schauer PR, Rosenblatt M et al. Quality of life after antireflux surgery compared with nonoperative management for severe gastroesophageal reflux disease. Journal of the American College of Surgeons 2002;(1):23–27.
26 Holzman MD, Mitchel EF, Ray WA, Smalley WE. Use of healthcare resources among medically and surgically treated patients with gastroesophageal reflux disease: a population-based study. Journal of the American College of Surgeons 2001;(1):17–24.
27 Isolauri J, Luostarinen M, Viljakka M, et al. Long-term comparison of antireflux surgery versus conservative therapy for reflux esophagitis. Annals of Surgery. 1997;225(3):295-9. [pmid: 9060586]. [pmcid: 1190680].
28 Johansson KE, Tibbling L. Maintenance treatment with ranitidine compared with fundoplication in gastro-oesophageal reflux disease. Scandinavian Journal of Gastroenterology. 1986;21(7):779-88. [pmid: 3535005].
29 Khaitan L, Ray WA, Holzman MD, Smalley WE. Health care utilization after medical and surgical therapy for gastroesophageal reflux disease: a population-based study, 1996 to 2000. Archives of Surgery. 2003;138(12):1356-61. [pmid: 14662539].
30 Tran T, Spechler SJ, Richardson P, ElSerag HB. Fundoplication and the risk of esophageal cancer in gastroesophageal reflux disease: a veterans affairs cohort study. American Journal of Gastroenterology. 2005;100(5):1002-8. [pmid: 15842570].
31 Wetscher GJ, Gadenstaetter M, Klingler PJ, et al. Efficacy of medical therapy and antireflux surgery to prevent Barrett's metaplasia in patients with gastroesophageal reflux disease.[see comment]. Annals of Surgery. 2001;234(5):627-32. [pmid: 11685025]. [pmcid: 1422086].
32 Ye W, Chow WH, Lagergren J, Yin L, Nyren O. Risk of adenocarcinomas of the esophagus and gastric cardia in patients with gastroesophageal reflux diseases and after antireflux surgery.[see comment]. Gastroenterology. 2001;121(6):1286-93. [pmid: 11729107].
33 McDonagh M, Carson S. Drug Class Review on Proton Pump Inhibitors. Final Report. 2005.
34 Caro JJ, Salas M, Ward A. Healing and relapse rates in gastroesophageal reflux disease treated with the newer proton-pump inhibitors lansoprazole, rabeprazole, and pantoprazole compared with omeprazole, ranitidine, and placebo: evidence from randomized clinical trials. Clinical Therapeutics. 2001;23(7):998-1017. [pmid: 11519776].
35 Donnellan C, Sharma N, Preston C, Moayyedi P. Medical treatments for the maintenance therapy of reflux oesophagitis and endoscopic negative reflux disease [Systematic Review]. Cochrane Database of Systematic Reviews 2005;(2).
36 Hagedorn C, Lonroth H, Rydberg L, Ruth M, Lundell L. Long-term efficacy of total (Nissen-Rossetti) and posterior partial (Toupet) fundoplication: results of a randomized clinical trial. Journal of Gastrointestinal Surgery. Aug. 2002;6(4):540-5. [pmid: 12127119].
37 Ludemann R, Watson DI, Jamieson GG, Game PA, Devitt PG. Five-year follow-up of a randomized clinical trial of laparoscopic total versus anterior 180 degrees fundoplication. Br J Surg. 2005;92(2):240-243. [pmid: 15609384].
38 Nilsson G, Wenner J, Larsson S, Johnsson F. Randomized clinical trial of laparoscopic versus open fundoplication for gastro-oesophageal reflux. British Journal of Surgery. 2004;91(5):552-9. [pmid: 15122604].
39 O'Boyle CJ, Watson DI, Jamieson GG, et al. Division of short gastric vessels at laparoscopic nissen fundoplication: a prospective double-blind randomized trial with 5-year follow-up. Ann Surg. 2002;235(2):165-170. [pmid: 11807353]. [pmcid: 1422409].
40 Granderath FA, Kamolz T, Schweiger UM, et al. Long-term results of laparoscopic antireflux surgery. Surgical Endoscopy. 2002;16(5):753-7. [pmid: 11997816].
41 Kamolz T, Granderath FA, Bammer T, Wykypiel H Jr, Pointner R. “Floppy” Nissen vs. Toupet laparoscopic fundoplication: quality of life assessment in a 5-year follow-up (part 2). Endoscopy. 2002;34(11):917-22. [pmid: 12430078].
42 Kamolz T, Granderath PA, Bammer T, et al. Mid- and long-term quality of life assessments after laparoscopic fundoplication and refundoplication: a single unit review of more than 500 antireflux procedures. Digestive & Liver Disease. 2002;34(7):470-6. [pmid: 12236479].
43 Patti MG, Robinson T, Galvani C et al. Total fundoplication is superior to partial fundoplication even when esophageal peristalsis is weak. Journal of the American College of Surgeons 2004;discussion-70.
44 Pelgrims N, Closset J, Sperduto N, Gelin M, Houben JJ. What did the laparoscopic Nissen approach of the gastro-oesophageal reflux really change for the patients 8 years later?. Acta Chirurgica Belgica. Apr. 2001;101(2):68-72. [pmid: 11396054].
45 Anvari M, Allen C. Five-year comprehensive outcomes evaluation in 181 patients after laparoscopic Nissen fundoplication. Journal of the American College of Surgeons 2003;discussion-8.
46 Bammer T, Hinder RA, Klaus A, Klingler PJ. Five- to eight-year outcome of the first laparoscopic Nissen fundoplications.[see comment]. Journal of Gastrointestinal Surgery. Feb. 2001;5(1):42-8. [pmid: 11309647].
47 Booth MI, Jones L, Stratford J, Dehn TC. Results of laparoscopic Nissen fundoplication at 2–8 years after surgery. British Journal of Surgery. 2002;89(4):476-81. [pmid: 11952591].
48 Granderath FA, Kamolz T, Schweiger UM, et al. Quality of life and symptomatic outcome three to five years after laparoscopic Toupet fundoplication in gastroesophageal reflux disease patients with impaired esophageal motility. American Journal of Surgery. 2002;183(2):110-6. [pmid: 11918872].
49 Lafullarde T, Watson DI, Jamieson GG, et al. Laparoscopic Nissen fundoplication: five-year results and beyond. Archives of Surgery. 2001;136(2):180-4. [pmid: 11177138].
50 Franzen T, Bostrom J, Tibbling GL, Johansson K. Prospective study of symptoms and gastro-oesophageal reflux 10 years after posterior partial fundoplication.[see comment]. British Journal of Surgery. 1999;86(7):956-60. [pmid: 10417573].
51 Grande L, ToledoPimentel V, Manterola C, et al. Value of Nissen fundoplication in patients with gastro-oesophageal reflux judged by long-term symptom control. British Journal of Surgery. 1994;81(4):548-50. [pmid: 8205432].
52 Henderson RD, Marryatt GV. Total fundoplication gastroplasty (Nissen gastroplasty): five-year review. Annals of Thoracic Surgery. 1985;39(1):74-9. [pmid: 3966839].
53 Luostarinen M. Nissen fundoplication for reflux esophagitis. Long-term clinical and endoscopic results in 109 of 127 consecutive patients. Annals of Surgery. 1993;217(4):329-37. [pmid: 8466307]. [pmcid: 1242799].
54 Cohen LB, Johnson DA, Ganz RA, et al. Enteryx implantation for GERD: expanded multicenter trial results and interim postapproval follow-up to 24 months. Gastrointest Endosc. 2005;61(6):650-658. [pmid: 15855967].
55 Lutfi RE, Torquati A, Kaiser J, Holzman M, Richards WO. Three year's experience with the Stretta procedure: did it really make a difference? Surgical Endoscopy 2005;(2):289–295.
56 Pleskow D, Rothstein R, Lo S, et al. Endoscopic full-thickness plication for the treatment of GERD: 12-month follow-up for the North American open-label trial. Gastrointest Endosc. 2005;61(6):643-649. [pmid: 15855966].
57 Triadafilopoulos G, DiBaise JK, Nostrant TT, et al. The Stretta procedure for the treatment of GERD: 6 and 12 month follow-up of the U.S. open label trial. Gastrointestinal Endoscopy. 2002;55(2):149-56. [pmid: 11818914].
58 Triadafilopoulos G. Changes in GERD symptom scores correlate with improvement in esophageal acid exposure after the Stretta procedure. Surgical Endoscopy. 2004;18(7):1038-44. [pmid: 15156392].
59 DiBaise JK, Brand RE, Quigley EM. Endoluminal delivery of radiofrequency energy to the gastroesophageal junction in uncomplicated GERD: efficacy and potential mechanism of action. American Journal of Gastroenterology. 2002;97(4):833-42. [pmid: 12003416].
60 Houston H, Khaitan L, Holzman M, Richards WO. First year experience of patients undergoing the Stretta procedure. Surgical Endoscopy. 2003;17(3):401-4. [pmid: 12436238].
61 Johnson DA, Ganz R, Aisenberg J, et al. Endoscopic implantation of enteryx for treatment of GERD: 12-month results of a prospective, multicenter trial.[see comment]. American Journal of Gastroenterology. 2003;98(9):1921-30. [pmid: 14499767].
62 Johnson DA, Ganz R, Aisenberg J, et al. Endoscopic, deep mural implantation of Enteryx for the treatment of GERD: 6-month follow-up of a multicenter trial.[see comment]. American Journal of Gastroenterology. 2003;98(2):250-8. [pmid: 12591037].
63 Pleskow D, Rothstein R, Lo S, et al. Endoscopic full-thickness plication for the treatment of GERD: a multicenter trial. Gastrointestinal Endoscopy. 2004;59(2):163-71. [pmid: 14745387].
64 Richards WO, Scholz S, Khaitan L, Sharp KW, Holzman MD. Initial experience with the stretta procedure for the treatment of gastroesophageal reflux disease. Journal of Laparoendoscopic & Advanced Surgical Techniques-Part A. 2001;11(5):267-73. [pmid: 11642661].
65 Richards WO, Houston HL, Torquati A et al. Paradigm shift in the management of gastroesophageal reflux disease. Annals of Surgery 237(5):638–47; discussion 648–9, 2003.
66 Torquati A, Houston HL, Kaiser J, Holzman MD, Richards WO. Long-term follow-up study of the Stretta procedure for the treatment of gastroesophageal reflux disease. Surgical Endoscopy. 2004;18(10):1475-9. [pmid: 15791372].
67 Triadafilopoulos G, DiBaise JK, Nostrant TT, et al. Radiofrequency energy delivery to the gastroesophageal junction for the treatment of GERD.[see comment]. Gastrointestinal Endoscopy. 2001;53(4):407-15. [pmid: 11275878].
68 Filipi CJ, Lehman GA, Rothstein RI, et al. Transoral, flexible endoscopic suturing for treatment of GERD: a multicenter trial.[see comment]. Gastrointestinal Endoscopy. 2001;53(4):416-22. [pmid: 11275879].
69 Chadalavada R, Lin E, Swafford V, Sedghi S, Smith CD. Comparative results of endoluminal gastroplasty and laparoscopic antireflux surgery for the treatment of GERD. Surgical Endoscopy. 2004;18(2):261-5. [pmid: 14691698].
70 Velanovich V, BenMenachem T, Goel S. Case-control comparison of endoscopic gastroplication with laparoscopic fundoplication in the management of gastroesophageal reflux disease: early symptomatic outcomes. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2002;12(4):219-23.
71 Wolfsen HC, Richards WO. The Stretta procedure for the treatment of GERD: a registry of 558 patients. Journal of Laparoendoscopic & Advanced Surgical Techniques-Part A. 2002;12(6):395-402. [pmid: 12590718].
72 Chen YK, Raijman I, Ben Menachem T, et al. Long-term outcomes of endoluminal gastroplication: a U.S. multicenter trial. Gastrointest Endosc. 2005;61(6):659-667. [pmid: 15855968].
73 Schumacher B, Neuhaus H, Ortner M, et al. Reduced medication dependency and improved symptoms and quality of life 12 months after enteryx implantation for gastroesophageal reflux. J Clin Gastroenterol. 2005;39(3):212-219. [pmid: 15718862].
74 AbouRebyeh H, Hoepffner N, Rosch T, et al. Long-term failure of endoscopic suturing in the treatment of gastroesophageal reflux: a prospective follow-up study. Endoscopy. 2005;37(3):213-6. [pmid: 15731936].
75 Schiefke I, ZabelLanghennig A, Neumann S, et al. Long term failure of endoscopic gastroplication (EndoCinch). Gut. 2005;54(6):752-8. [pmid: 15888777]. [pmcid: 1774515].
76 Deviere J, Pastorelli A, Louis H, et al. Endoscopic implantation of a biopolymer in the lower esophageal sphincter for gastroesophageal reflux: a pilot study. Gastrointestinal Endoscopy. 2002;55(3):335-41. [pmid: 11868005].
77 Go MR, Dundon JM, Karlowicz DJ, et al. Delivery of radiofrequency energy to the lower esophageal sphincter improves symptoms of gastroesophageal reflux. Surgery. 2004;136(4):786-94. [pmid: 15467663].
78 Tam WC, Schoeman MN, Zhang Q, et al. Delivery of radiofrequency energy to the lower oesophageal sphincter and gastric cardia inhibits transient lower oesophageal sphincter relaxations and gastro-oesophageal reflux in patients with reflux disease. Gut. 2003;52(4):479-85. [pmid: 12631654]. [pmcid: 1773620].
79 Arts J, Lerut T, Rutgeerts P, et al. A one-year follow-up study of endoluminal gastroplication (Endocinch) in GERD patients refractory to proton pump inhibitor therapy. Digestive Diseases & Sciences. 2005;50(2):351-6. [pmid: 15745100].
80 Mahmood Z, McMahon BP, Arfin Q, et al. Endocinch therapy for gastro-oesophageal reflux disease: a one year prospective follow up. Gut. 2003;52(1):34-9. [pmid: 12477756]. [pmcid: 1773510].
81 Tam WC, Holloway RH, Dent J, Rigda R, Schoeman MN. Impact of endoscopic suturing of the gastroesophageal junction on lower esophageal sphincter function and gastroesophageal reflux in patients with reflux disease.[see comment]. American Journal of Gastroenterology. 2004;99(2):195-202. [pmid: 15046204].
82 Parrilla P, Martinez de Haro LF, Ortiz A, et al. Long-term results of a randomized prospective study comparing medical and surgical treatment of Barrett's esophagus.[see comment]. Annals of Surgery. 2003;237(3):291-8. [pmid: 12616111]. [pmcid: 1514316].
83 Ortiz A, Martinez de Haro LF, Parrilla P, et al. Conservative treatment versus antireflux surgery in Barrett's oesophagus: long-term results of a prospective study.[see comment]. British Journal of Surgery. 1996;83(2):274-8. [pmid: 8689188].
84 Bammer T, Hinder RA, Klaus A, Trastek VF, Achem SR. Rationale for surgical therapy of Barrett esophagus. [Review] [84 refs]. Mayo Clinic Proceedings. 2001;76(3):335-42. [pmid: 11243284].
85 Corey KE, Schmitz SM, Shaheen NJ. Does a surgical antireflux procedure decrease the incidence of esophageal adenocarcinoma in Barrett's esophagus? A meta-analysis.[see comment]. Am J Gastroenterol. 2003;98(11):2390-2394. [pmid: 14638338].
86 Campos GM, Peters JH, DeMeester TR, et al. Multivariate analysis of factors predicting outcome after laparoscopic Nissen fundoplication. Journal of Gastrointestinal Surgery. Jun. 1999;3(3):292-300. [pmid: 10481122].
87 Horvath KD, Jobe BA, Herron DM, Swanstrom LL. Laparoscopic Toupet fundoplication is an inadequate procedure for patients with severe reflux disease. Journal of Gastrointestinal Surgery. Dec. 1999;3(6):583-91. [pmid: 10554364].
88 Ritter MP, Peters JH, DeMeester TR, et al. Outcome after laparoscopic fundoplication is not dependent on a structurally defective lower esophageal sphincter. Journal of Gastrointestinal Surgery. Dec. 1998;2(6):567-72. [pmid: 10457315].
89 Jackson PG, Gleiber MA, Askari R, Evans SR. Predictors of outcome in 100 consecutive laparoscopic antireflux procedures. American Journal of Surgery. 2001;181(3):231-5. [pmid: 11376577].
90 Booth M, Stratford J, Dehn TC. Preoperative esophageal body motility does not influence the outcome of laparoscopic Nissen fundoplication for gastroesophageal reflux disease. Diseases of the Esophagus. 2002;15(1):57-60. [pmid: 12060044].
91 Desai KM, Frisella MM, Soper NJ. Clinical outcomes after laparoscopic antireflux surgery in patients with and without preoperative endoscopic esophagitis. Journal of Gastrointestinal Surgery. 2003;7(1):44-51. discussion 51–2. [pmid: 12559184].
92 O'Boyle CJ, Watson DI, DeBeaux AC, Jamieson GG. Preoperative prediction of long-term outcome following laparoscopic fundoplication. ANZ Journal of Surgery. 2002;72(7):471-5. [pmid: 12123502].
93 Power C, Maguire D, McAnena O. Factors contributing to failure of laparoscopic Nissen fundoplication and the predictive value of preoperative assessment. American Journal of Surgery. 2004;187(4):457-63. [pmid: 15041491].
94 Khajanchee YS, Hong D, Hansen PD, Swanstrom LL. Outcomes of antireflux surgery in patients with normal preoperative 24-hour pH test results. American Journal of Surgery. 2004;187(5):599-603. [pmid: 15135673].
95 Sandbu R, Khamis H, Gustavsson S, Haglund U. Laparoscopic antireflux surgery in routine hospital care. Scandinavian Journal of Gastroenterology. 2002;37(2):132-7. [pmid: 11843046].
96 Winslow ER, Frisella MM, Soper NJ, Klingensmith ME. Obesity does not adversely affect the outcome of laparoscopic antireflux surgery (LARS). Surgical Endoscopy. 2003;17(12):2003-11. [pmid: 14577029].
97 Topart P, Vandenbroucke F, Robaszkiewicz M, Lozac'h P. Prognostic value of the lower esophageal sphincter gradient and acid exposure in the follow-up of antireflux operations. Diseases of the Esophagus. 1999;12(1):22-7. [pmid: 10941856].
98 Yau P, Watson DI, Jamieson GG, Myers J, Ascott N. The influence of esophageal length on outcomes after laparoscopic fundoplication. Journal of the American College of Surgeons 2000;(4):360–365.
99 Costantini M, Zaninotto G, Anselmino M, et al. The role of a defective lower esophageal sphincter in the clinical outcome of treatment for gastroesophageal reflux disease. Archives of Surgery. 1996;131(6):655-9. [pmid: 8645075].
100 Carlsson R,, Galmiche JP, Dent J, Lundell L, Frison L. Prognostic factors influencing relapse of oesophagitis during maintenance therapy with antisecretory drugs: a meta-analysis of long-term omeprazole trials. Alimentary Pharmacology & Therapeutics. 1997;11(3):473-82. [pmid: 9218069].
101 Berenson MM, Sontag S, Robinson MG, McCallum RM. Effect of smoking in a controlled study of ranitidine treatment in gastroesophageal reflux disease. J Clin Gastroenterol. 1987;9(5):499-503. [pmid: 3316371].
102 Collen MJ, Abdulian JD, Chen YK. Gastroesophageal reflux disease in the elderly: more severe disease that requires aggressive therapy. American Journal of Gastroenterology. 1995;90(7):1053-7. [pmid: 7611195].
103 Klaus A, Hinder RA, DeVault KR, Achem SR. Bowel dysfunction after laparoscopic antireflux surgery: incidence, severity, and clinical course.[see comment]. American Journal of Medicine. 2003;114(1):6-9. [pmid: 12543282].
104 Hwang H, Turner LJ, Blair NP. Examining the learning curve of laparoscopic fundoplications at an urban community hospital. American Journal of Surgery. 2005;189(5):522-6. discussion 526. [pmid: 15862489].
105 Menon VS, Manson JM, Baxter JN. Laparoscopic fundoplication: learning curve and patient satisfaction. Annals of the Royal College of Surgeons of England. 2003;85(1):10-3. [pmid: 12585623]. [pmcid: 1964343].
106 Voitk A, Joffe J, Alvarez C, Rosenthal G. Factors contributing to laparoscopic failure during the learning curve for laparoscopic Nissen fundoplication in a community hospital. Journal of Laparoendoscopic & Advanced Surgical Techniques-Part A. 1999;9(3):243-8. [pmid: 10414540].
107 Soot SJ, Eshraghi N, Farahmand M, Sheppard BC, Deveney CW. Transition from open to laparoscopic fundoplication: the learning curve. Archives of Surgery. 1999;134(3):278-81. discussion 282. [pmid: 10088568].
108 Watson DI, Baigrie RJ, Jamieson GG. A learning curve for laparoscopic fundoplication. Definable, avoidable, or a waste of time?. Annals of Surgery. 1996;224(2):198-203. [pmid: 8757384]. [pmcid: 1235342].
109 Blom D, Peters JH, DeMeester TR, et al. Physiologic mechanism and preoperative prediction of new-onset dysphagia after laparoscopic Nissen fundoplication. Journal of Gastrointestinal Surgery. Feb. 2002;6(1):22-7. discussion 27–8. [pmid: 11986014].
110 Brunt LM, Quasebarth MA, Dunnegan DL, Soper NJ. Is laparoscopic antireflux surgery for gastroesophageal reflux disease in the elderly safe and effective?. Surgical Endoscopy. 1999;13(9):838-42. [pmid: 10449835].
111 Fernando HC, Schauer PR, Buenaventura PO, et al. Outcomes of minimally invasive antireflux operations in the elderly: a comparative review. Journal of the Society of Laparoendoscopic Surgeons. Dec. 2003;7(4):311-5. [pmid: 14626396].
112 Khajanchee YS, Urbach DR, Butler N, Hansen PD, Swanstrom LL. Laparoscopic antireflux surgery in the elderly.[see comment]. Surgical Endoscopy. 2002;16(1):25-30. [pmid: 11961599].
113 Stewart GD, Watson AJ, Lamb PJ, et al. Comparison of three different procedures for antireflux surgery. British Journal of Surgery. 2004;91(6):724-9. [pmid: 15164442].
114 Kamolz T, Bammer T, Granderath FA, Pasiut M, Pointner R. Quality of life and surgical outcome after laparoscopic antireflux surgery in the elderly gastroesophageal reflux disease patient. Scand J Gastroenterol. 2001;36(2):116-120. [pmid: 11252401].
115 Bammer T, Hinder RA, Klaus A, et al. Safety and long-term outcome of laparoscopic antireflux surgery in patients in their eighties and older. Surgical Endoscopy. 2002;16(1):40-2. [pmid: 11961602].
116 Bell RC, Hanna P, Mills MR, Bowrey D. Patterns of success and failure with laparoscopic Toupet fundoplication. Surgical Endoscopy. 1999;13(12):1189-94. [pmid: 10594263].
117 Fraser J, Watson DI, O'Boyle CJ, Jamieson GG. Obesity and its effect on outcome of laparoscopic Nissen fundoplication. Diseases of the Esophagus. 2001;14(1):50-3. [pmid: 11422306].
118 Perez AR, Moncure AC, Rattner DW. Obesity adversely affects the outcome of antireflux operations.[see comment]. Surgical Endoscopy. 2001;15(9):986-9. [pmid: 11443428].
119 Velanovich V, KarmyJones R. Psychiatric disorders affect outcomes of antireflux operations for gastroesophageal reflux disease.[see comment]. Surgical Endoscopy. 2001;15(2):171-5. [pmid: 11285962].
120 Kamolz T, Granderath FA, Pointner R. Does major depression in patients with gastroesophageal reflux disease affect the outcome of laparoscopic antireflux surgery?. Surgical Endoscopy. 2003;17(1):55-60. [pmid: 12239650].
121 Kamolz T, Bammer T, Pointner R. Predictability of dysphagia after laparoscopic nissen fundoplication. American Journal of Gastroenterology. 2000;95(2):408-14. [pmid: 10685742].
122 Patti MG, Perretta S, Fisichella PM, et al. Laparoscopic antireflux surgery: preoperative lower esophageal sphincter pressure does not affect outcome. Surgical Endoscopy. 2003;17(3):386-9. [pmid: 12436239].
123 Haithcock B, Velanovich V. Comparison of antireflux surgery among ethnicity. Journal of the National Medical Association. 2004;96(4):535-41. [pmid: 15101673].
124 Kamolz T, Bammer T, Granderath FA, Pointner R. Comorbidity of aerophagia in GERD patients: outcome of laparoscopic antireflux surgery. Scandinavian Journal of Gastroenterology. 2002;37(2):138-43. [pmid: 11843047].
125 Xenos ES, Reinker D, Mogerman D. Early experience with laparoscopic antireflux surgery in the rural setting. Southern Medical Journal. 2001;94(1):43-6. [pmid: 11213941].
126 Hollenbeck JI, Woodward ER. Treatment of Peptic Esophageal Stricture with Combined Fundic Patch-fundoplication. Ann Surg. 1975;182(4):472-477. [pmid: 1180584]. [pmcid: 1344015].
127 Payne WS, Trastek VF, Pairolero PC. Reflux esophagitis. Surg Clin North Am. 1987;67(3):443-454. [pmid: 3589899].
128 Shirazi SS, Schulze K, Soper RT. Long-term Follow-up for Treatment of Complicated Chronic Reflux Esophagitis. Archives of Surgery. 1987;122:548-552. [pmid: 3579565].
129 Metz DC, Bochenek WJ. Pantoprazole US GERD Study Group. Pantoprazole maintenance therapy prevents relapse of erosive oesophagitis. Alimentary Pharmacology & Therapeutics. 2003;17(1):155-64. [pmid: 12492745].
130 Caos A, Breiter J, Perdomo C, Barth J. Long-term prevention of erosive or ulcerative gastro-oesophageal reflux disease relapse with rabeprazole 10 or 20 mg vs. placebo: results of a 5-year study in the United States. Aliment Pharmacol Ther. 2005;22(3):193-202. [pmid: 16091056].
131 Thjodleifsson B, Rindi G, Fiocca R, et al. A randomized, double-blind trial of the efficacy and safety of 10 or 20 mg rabeprazole compared with 20 mg omeprazole in the maintenance of gastro-oesophageal reflux disease over 5 years. Alimentary Pharmacology & Therapeutics. 2003;17(3):343-51. [pmid: 12562446].
132 Claessens AA, Heerdink ER, van Eijk JT, Lamers CB, Leufkens HG. Characteristics of diarrhoea in 10,008 users of lansoprazole in daily practice: which co-factors contribute?. Pharmacoepidemiology & Drug Safety. 2002;11(8):703-8. [pmid: 12512247].
133 Klinkenberg-Knol EC, Nelis F, Dent J, et al. Long-term omeprazole treatment in resistant gastroesophageal reflux disease: efficacy, safety, and influence on gastric mucosa. Gastroenterology. 2000;118(4):661-669. [pmid: 10734017].
134 Cunningham R, Dale B, Undy B, Gaunt N. Proton pump inhibitors as a risk factor for Clostridium difficile diarrhoea. Journal of Hospital Infection. 2003;54(3):243-5. [pmid: 12855243].
135 Andersson T, Hassan-Alin M, Hasselgren G, Rohss K. Drug interaction studies with esomeprazole, the (S)-isomer of omeprazole. Clin Pharmacokinet. 2001;40(7):523-537. [pmid: 11510629].
136 Welage LS. Overview of pharmacologic agents for acid suppression in critically ill patients. Am J Health Syst Pharm. 2005;62(10 Suppl 2):S4-S10. [pmid: 15905600].
137 Carlson MA, Frantzides CT. Complications and results of primary minimally invasive antireflux procedures: a review of 10,735 reported cases. [Review][88 refs]. Journal of the American College of Surgeons 2001;(4):428–439.
138 Catarci M, Gentileschi P, Papi C, et al. Evidence-based appraisal of antireflux fundoplication. [Review] [113 refs]. Annals of Surgery. 2004;239(3):325-37. [pmid: 15075649]. [pmcid: 1356230].
139 Flum DR, Koepsell T, Heagerty P, Pellegrini CA. The nationwide frequency of major adverse outcomes in antireflux surgery and the role of surgeon experience, 1992-1997. J Am Coll Surg. 2002;195(5):611-618. [pmid: 12437246].
140 Anvari M, Allen CJ. Prospective evaluation of dysphagia before and after laparoscopic Nissen fundoplication without routine division of short gastrics. Surgical Laparoscopy & Endoscopy. 1996;6(6):424-9. [pmid: 8948032].
141 Anvari M, Allen C. Esophageal and lower esophageal sphincter pressure profiles 6 and 24 months after laparoscopic fundoplication and their association with postoperative dysphagia. Surgical Endoscopy. 1998;12(5):421-6. [pmid: 9569362].
142 Anvari M, Allen C. Laparoscopic Nissen fundoplication: two-year comprehensive follow-up of a technique of minimal paraesophageal dissection. Annals of Surgery. 1998;227(1):25-32. [pmid: 9445106]. [pmcid: 1191168].
143 Anvari M, Allen C. Postprandial bloating after laparoscopic Nissen fundoplication.[see comment]. Canadian Journal of Surgery. 2001;44(6):440-4.
144 Coelho JC, Campos AC, Costa MA, Soares RV, Faucz RA. Complications of laparoscopic fundoplication in the elderly. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2003;13(1):6-10.
145 Dally E, Falk GL. Teflon pledget reinforced fundoplication causes symptomatic gastric and esophageal lumenal penetration. American Journal of Surgery. 2004;187(2):226-9. [pmid: 14769309].
146 Leggett PL, Bissell CD, Churchman Winn R, Ahn C. A. comparison of laparoscopic Nissen fundoplication and Rossetti's modification in 239 patients. Surgical Endoscopy. 2000;14(5):473-7. [pmid: 10858475].
147 O'Boyle CJ, Heer K, Smith A, et al. Iatrogenic thoracic migration of the stomach complicating laparoscopic nissen fundoplication.[see comment]. Surgical Endoscopy. 2000;14(6):540-2. [pmid: 10890961].
148 Sato K, Awad ZT, Filipi CJ, et al. Causes of long-term dysphagia after laparoscopic Nissen fundoplication. Journal of the Society of Laparoendoscopic Surgeons. Mar. 2002;6(1):35-40. [pmid: 12002294].
149 Seelig MH, Hinder RA, Klingler PJ, et al. Paraesophageal herniation as a complication following laparoscopic antireflux surgery. Journal of Gastrointestinal Surgery. Feb. 1999;3(1):95-9. [pmid: 10457330].
150 Walsh JD, Landercasper J, Boyd WC, Lambert PJ, Havlik PJ. Patient outcomes and dysphagia after laparoscopic antireflux surgery performed without use of intraoperative esophageal dilators. American Surgeon. 2003;69(3):219-23. discussion 223–4. [pmid: 12678478].
151 Arts J, Vos R, Gebruers K. Radiofrequency delivery (the Stretta Procedure) reduces the distensibility of the gastro-esophageal junction in GERD patients. (abstract). Digestive Disease Week and the 106th Annual Meeting of the American Gastroenterological Association. May 14–19, 2005, Chicago, Illinois, USA. Abstracts. Gastroenterology. 2005;128(4 Suppl 2):A1-821. [pmid: 15900640].
152 Noh KW, Loeb DS, Stockland A, Achem SR. Pneumomediastinum following Enteryx injection for the treatment of gastroesophageal reflux disease. American Journal of Gastroenterology. 2005;100(3):723-6. [pmid: 15743374].
153 Wong RF, Davis TV, Peterson KA. Complications involving the mediastinum after injection of Enteryx for GERD. Gastrointest Endosc. 2005;61(6):753-756. [pmid: 15855987].
154 Tintillier M, Chaput A, Kirch L, et al. Esophageal abscess complicating endoscopic treatment of refractory gastroesophageal reflux disease by Enteryx injection: a first case report. American Journal of Gastroenterology. 2004;99(9):1856-8. [pmid: 15330928].
155 Barlow WJ, Orlando RC. The pathogenesis of heartburn in nonerosive reflux disease: a unifying hypothesis. Gastroenterology. 2005;128(3):771-778. [pmid: 15765412].
156 Martinez SD, Malagon IB, Garewal HS, Cui H, Fass R. Non-erosive reflux disease (NERD)--acid reflux and symptom patterns. Aliment Pharmacol Ther. 2003;17(4):537-545. [pmid: 12622762].
157 Khajanchee YS, O'Rourke RW, Lockhart B, et al. Postoperative symptoms and failure after antireflux surgery. Arch Surg. 2002;137(9):1008-1013. [pmid: 12215150].
158 Lord RV, Kaminski A, Oberg S, et al. Absence of gastroesophageal reflux disease in a majority of patients taking acid suppression medications after Nissen fundoplication. J Gastrointest Surg. 2002;6(1):3-9. [pmid: 11986011].
159 Velanovich V. Medication usage and additional esophageal procedures after antireflux surgery. Surg Laparosc Endosc Percutan Tech. 2003;13(3):161-164. [pmid: 12819498].

## References for Appendix F

1 Arts J, Vos R, Gebruers K. Radiofrequency delivery (the Stretta Procedure) reduces the distensibility of the gastro-esophageal junction in GERD patients. (abstract). Digestive Disease Week and the 106th Annual Meeting of the American Gastroenterological Association. May 14–19, 2005, Chicago, Illinois, USA. Abstracts. Gastroenterology. 2005;128(4 Suppl 2):A1-821. [pmid: 15900640].
2 Mason RJ, Hughes M, Lehman GA, et al. Endoscopic augmentation of the cardia with a biocompatible injectable polymer (Enteryx) in a porcine model.[see comment]. Surgical Endoscopy. 2002;16(3):386-91. [pmid: 11928013].
3 Kadirkamanathan SS, Evans DF, Gong F, et al. Antireflux operations at flexible endoscopy using endoluminal stitching techniques: an experimental study. Gastrointestinal Endoscopy. 1996;44(2):133-43. [pmid: 8858318].
4 Kadirkamanathan SS, Yazaki E, Evans DF, et al. An ambulant porcine model of acid reflux used to evaluate endoscopic gastroplasty. Gut. 1999;44(6):782-8. [pmid: 10323878]. [pmcid: 1727549].
5 Chuttani R, Kozarek R, Polavaram V. A novel endoscopic full thickness plicator for the treatment of GERD: Efficacy in an ex-vivo porcine model (Abstract). Gastrointest Endosc. 2001;53:132.
6 Cicala M, Gabbrielli A, Emerenziani S, et al. Effect of endoscopic augmentation of the lower oesophageal sphincter (Gatekeeper reflux repair system) on intraoesophageal dynamic characteristics of acid reflux. Gut. 2005;54(2):183-186. [pmid: 15647177]. [pmcid: 1774830].
7 Fockens P. Gatekeeper Reflux Repair System: technique, pre-clinical, and clinical experience. [Review] [10 refs]. Gastrointestinal Endoscopy Clinics of North America. 2003;13(1):179-89. [pmid: 12797437].
8 Corley DA, Katz P, Wo JM, et al. Improvement of gastroesophageal reflux symptoms after radiofrequency energy: a randomized, sham-controlled trial.[see comment]. Gastroenterology. 2003;125(3):668-76. [pmid: 12949712].
9 Deviere J, Costamagna G, Neuhaus H, et al. Nonresorbable copolymer implantation for gastroesophageal reflux disease: a randomized sham-controlled multicenter trial.[see comment]. Gastroenterology. 2005;128(3):532-40. [pmid: 15765387].
10 Park PO, Hall-Angeras M, Ohlin M, et al. A prospective, multicneter, randomized, single-blind parallel group study on the comparison between endoscopic cardia suturing and sham operation as a treatement of patients with gastroesophageal reflux symptoms. Gastroenterology. 2005;128(4 Suppl 2):A95.
11 Rothstein RI, Hynes ML, Grove MR, Pho H. Endoscopic gastric plication (EndoCinch) for GERD: A randomized, sham-controlled, blinded, single-center study (abstract). Gastrointest Endosc. 2004;59(4):AB111.
12 Schwartz MP, Wellink H, Gooszen HG, Samsom M, Smout AJ. A blinded, randomized, sham-controlled trial of endoscopic gastroplication for the treatment of gastro-esophageal reflux disease (GERD): Preliminary results. Abstract 496. Digestive Disease Week, American Society for Gastrointestinal Endoscopy meeting abstracts. May 2005, Chicago, Illinois, USA. Gastrointestinal Endoscopy. 2005;61(5):AB95.
13 Lehman GA, Chen YK, Mondolia TF. Improved acid exposure and symptom scores 3 months post-ENTERYX: Initial US randomized controlled trials resuts (Abstract). Digestive Disease Week and the 106th Annual Meeting of the American Gastroenterological Association. May 14–19, 2005, Chicago, Illinois, USA. Gastroenterology 2005; 128((4,Suppl 2)).
14 Domagk D, Menzel J, Seidel M, et al. Endoluminal gastroplasty versus endoscopic polymer implantation for treatment of GERD: Preliminary 6-months results of a prospective randomized trial. Abstract. Digestive Disease Week and the 106th Annual Meeting of the American Gastroenterological Association. May 14–19, 2005, Chicago, Illinois, USA. Gastroenterology. 2005;128(4 Suppl 2:):A1-821. [pmid: 15900640].
15 AbouRebyeh H, Hoepffner N, Rosch T, et al. Long-term failure of endoscopic suturing in the treatment of gastroesophageal reflux: a prospective follow-up study. Endoscopy. 2005;37(3):213-6. [pmid: 15731936].
16 Schiefke I, ZabelLanghennig A, Neumann S, et al. Long term failure of endoscopic gastroplication (EndoCinch). Gut. 2005;54(6):752-8. [pmid: 15888777]. [pmcid: 1774515].
17 Cohen LB, Johnson DA, Ganz RA, et al. Enteryx implantation for GERD: expanded multicenter trial results and interim postapproval follow-up to 24 months. Gastrointest Endosc. 2005;61(6):650-658. [pmid: 15855967].