# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

## Technical Expert Panel

- Peter Bonis, MD
- Assistant Professor
- Tufts University School of Medicine
- Boston, MA
- Deputy Editor and Director of Clinical Research
- UpToDate, Inc
- Wellesley, MA

- Ronald Hinder, MD, PhD
- Professor and Chairman,
- Department of Surgery
- Mayo Clinic College of Medicine
- Mayo Clinic Jacksonville
- Jacksonville, Florida

- Kenneth R. DeVault, MD, FACG
- Professor of Medicine
- Mayo Clinic College of Medicine
- Director of Research
- Gastrointestinal Research,
- Division of Gastroenterology & Hepatology
- Department of Internal Medicine
- Mayo Clinic Jacksonville
- Jacksonville, FL

- Richard Sampliner, MD
- Professor of Medicine
- University of Arizona
- Chief, Gastroenterology Section
- Tucson VA Medical Center
- Southern Arizona VA Health Care System
- Tucson, AZ

## AHRQ Contact

- Kenneth S. Fink, MD, MGA, MPH
- Director
- Evidence-based Practice Centers Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD
- epc@ahrq.gov