# Introduction

Gastroesophageal reflux disease (GERD) has been defined as symptoms or mucosal damage caused by the abnormal reflux of gastric contents into the esophagus. ^1^ A systematic review of 15 epidemiologic studies estimated an overall prevalence of 10 to 20 percent in the Western world when GERD was defined as at least weekly heartburn and/or acid regurgitation. ^2^ Direct costs attributable to GERD were estimated to be $10 billion in the United States in 2000. ^3^

Optimal strategies for evaluating patients suspected of having GERD remain unclear. National guidelines endorse an initial trial of empirical therapy in patients with symptoms suggesting uncomplicated GERD, reserving endoscopy for those with risk factors for Barrett's esophagus or certain alarm features such as dysphagia. ^1^ However, a variety of upper digestive symptoms have features that may resemble GERD while several disorders (such as asthma, laryngitis, and chronic cough) have been attributed to GERD even in patients who do not have heartburn or regurgitation. Furthermore, a clinical response to an empiric trial with proton pump inhibitors (PPIs) does not confidently establish the diagnosis of GERD when GERD is defined using objective reference standards. ^4^

Most authorities consider the goals of therapy to be improvement in symptoms and quality of life, healing of and maintenance of healed erosive esophagitis, and prevention of complications (such as Barrett's esophagus, esophageal stricture formation, or esophageal adenocarcinoma). However, there remains considerable uncertainty regarding how these objectives should be achieved. ^5^ Among patients treated medically, there are several approaches that are used depending in part upon the severity of symptoms and clinical response including lifestyle modifications, intermittent, periodic, or continuous use of prescription or over-the-counter histamine type 2 receptor antagonists (H2RAs) and PPIs. Objective criteria for how these approaches should be used (and their cost-effectiveness) have not been defined clearly.

The availability of endoscopic and surgical treatments for GERD has further complicated management strategies. The endoscopic approaches in particular have drawn into focus the disparities that can exist among various objectives in treating GERD. The endpoints of endoscopic therapies have included changes in symptoms, quality of life, healing of esophagitis, improvement in esophageal pH studies, and reduction in the need for maintenance antisecretory treatment (particularly PPIs). While ideally these endpoints would occur concordantly, improvement in symptoms or a reduction in the need for antisecretory medications have not consistently correlated with objective measures such as normalization of esophageal pH ^6^ exposure or healing of esophagitis. ^7^ Furthermore, while a reduction in the required daily dose of a PPI may have favorable economic consequences, the benefit (from the perspective of a patient who continues to require daily antisecretory therapy) is uncertain. The durability of benefit is also unclear.

Similarly, while surgery has been considered to provide an alternative to permanent use of antisecretory medications, long-term follow-up of a landmark randomized controlled trial (RCT) comparing medical with surgical approaches found that approximately two-thirds of surgically treated patients required regular antireflux medications. ^8^ In addition, while advocates of surgery continue to suggest that it might be more effective than medical therapy for prevention of Barrett's esophagus and esophageal cancer, evidence supporting this assertion has been inconclusive. Whether surgery has a role in patients whose symptoms are refractory to medical therapy continues to be controversial, particularly since consensus has not been achieved on the definition of “refractory” GERD.

Treatment with PPIs is considered to be the standard against which other approaches to GERD can be compared. However, while PPIs have proven to be generally safe, there continues to be lingering concerns related to safety with life-long use. Adverse effects reported with PPIs include a possible increase in the risk of enteric infections ^9,^ ^10^ and community acquired pneumonia. ^11^ Also unsettled are concerns related to prolonged hypergastrinemia ^12^ and atrophic gastritis in the setting of Helicobacter pylori infection. ^13,^ ^14^

## Scope and Key Questions

This report summarizes the available evidence comparing the efficacy and safety of medical, surgical, and endoscopic approaches in the treatment of chronic GERD, particularly after long-term follow-up. Key questions addressed in this report are:

1 What is the evidence of the comparative effectiveness of medical, surgical, and endoscopic, treatments for improving objective and subjective outcomes in patients with chronic GERD? Is there evidence that effectiveness varies by specific techniques/procedures or medications? Objective outcomes include esophagitis healing, ambulatory pH, other indicators of reflux, need for medication, healthcare utilization, and incidence of esophageal stricture, Barrett's esophagus, or esophageal adenocarcinoma. Subjective outcomes include symptom frequency and severity, sleep/productivity, and overall quality of life.
2 Is there evidence that effectiveness of medical, surgical, and endoscopic treatments vary for specific patient subgroups? What are the characteristics of patients who have undergone these therapies, including the nature of previous medical therapy, severity of symptoms, age, sex, weight, other demographic and medical factors, or by specific patient subgroups, and provider characteristics for procedures including provider volume and setting (eg, academic versus community)?
3 What are the short- and long-term adverse effects associated with specific medical, surgical, and endoscopic therapies for GERD? Does the incidence of adverse effects vary with duration of follow-up, specific surgical intervention, or patient characteristics?

The following is a brief description of the participants, interventions, outcome measures, and the types of studies reviewed in this report. A detailed discussion of the study selection criteria is provided in the Methods section.

### Types of participants

The population of interest for this report is adults with chronic GERD. Because of the variability in definitions of GERD, this report includes population with a diagnosis of GERD based on any commonly used criteria including an abnormal ambulatory pH study, endoscopic esophagitis, typical symptoms of GERD (heartburn or regurgitation), a response to a therapeutic trial of a proton pump inhibitor, and other definitions.

### Types of interventions

The interventions of interest are medical, surgical, and endoscopic treatments. Medical treatments include PPIs or H2RAs. Surgical treatments include total or partial fundoplication, either as an open or as a laparoscopic procedure. Endoscopic treatments include endoscopic suturing, radiofrequency energy delivery to the gastroesophageal junction, or implantation of inert polymers.

### Types of outcome measures

Subjective outcomes of interest are GERD-related symptoms and patient's quality of life (QOL). Objective outcomes include esophageal acid exposure, status of esophagitis, lower esophageal sphincter competence, use of antireflux medications, incidence of Barrett's esophagus and esophageal adenocarcinoma.

### Types of studies

For comparing efficacy between a medical treatment and a surgical procedure, we retrieved all randomized and non-randomized comparative studies. For interclass and intraclass comparison of medical treatments, we used information from recent meta-analyses. For comparison of surgical techniques, we included randomized and non-randomized comparative studies. To supplement data on long-term efficacy of surgery, we also included surgical cohort studies. For endoscopic procedures, we used both comparative and cohort studies.