# Gastroesophageal Reflux Disease-Health-Related Quality-of-Life Scale

## Gastroesophageal Reflux Disease-Health-Related Quality-of-Life Scale

### Scoring Scale

0 = No symptoms

1 = Symptoms noticeable but not bothersome

2 = Symptoms noticeable and bothersome but not every day

3 = Symptoms bothersome every day

4 = Symptoms affect daily activities

5 = Symptoms are incapacitating - unable to do activities

### Questions about symptoms (circle one of each question)

1. How bad is your heartburn? | 0 | 1 | 2 | 3 | 5
2. Heartburn when lying down? | 0 | 1 | 2 | 3 | 5
3. Heartburn when standing up? | 0 | 1 | 2 | 3 | 5
4. Heartburn after meals? | 0 | 1 | 2 | 3 | 5
5. Does heartburn change your diet? | 0 | 1 | 2 | 3 | 5
6. Does heartburn wake you from sleep? | 0 | 1 | 2 | 3 | 5
7. Do you have difficulty swallowing? | 0 | 1 | 2 | 3 | 5
8. Do you have pain with swallowing? | 0 | 1 | 2 | 3 | 5
9. If you take medication, does this affect your daily life? | 0 | 1 | 2 | 3 | 5
10. How satisfied are you with your present condition? | Satisfied | Neutral | Dissatisfied

Reprinted from JOURNAL OF GASTROINTESTINAL SURGERY, 2(2), Velanovich V, “Comparison of Generic(SF-36) vs. Disease Specific Quality-of-Life (GERD-HRQL) Scales for Gastroesophageal Reflux Disease”, 141–145, (c) 1998, with permission of Society for Surgery of the Alimentary Tract.