# Common Esophagitis Grading Scales

## Common Esophagitis Grading Scales

Savary-Miller

Grade I: one or more supravestibular, non-confluent reddish spots, with or without exudates

Grade II: erosive and exudative lesions in the distal esophagus, which may be confluent but not

involving entire circumference

Grade III: circumferential erosions in the distal esophagus, covered by hemorrhagic and pseudomembranous exudates

Grade IV: presence of chronic complications such as deep ulcers, stenosis, or scarring with Barrett's metaplasia

Los Angeles Classification

Not present: No breaks (erosions) in the esophageal mucosa (edema, erythema, or friability may be present)

Grade A: One or more mucosal breaks confined to the mucosal folds, each not more than 5 mm in maximum length

Grade B: One or more mucosal breaks more than 5 mm in maximum length, but not continuous between the tops of two mucosal folds

Grade C: Mucosal breaks those are continuous between the tops of two or more mucosal folds, but which involve less than 75% of the esophageal circumference

Grade D: Mucosal breaks, which involve at least 75% of the esophageal circumference.

The presence or absence of strictures, ulcers, and /or Barrett's esophagus must be noted separately, e.g., “Grade B with stricture”