# Peer Reviewers

## Peer Reviewers

Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease

- Greg Amante
- Senior Product Manager
- Davol, Inc.
- Subsidiary of C.R. Bard, Inc.
- Cranston, RI

- Jeffrey H. Peters, M.D., FACS
- Seymour I. Schwartz Professor and Chairman
- University of Rochester School of Medicine and Dentistry
- Surgeon-in-Chief Strong Memorial Hospital
- Department of Surgery
- Rochester, NY
- Representative of Society for Surgery of the Alimentary Tract

- Gary W. Falk, MD
- Professor of Medicine
- Cleveland Clinic Lerner College of Medicine
- Director, Center for Swallowing and Esophageal Disorders
- Department of Gastroenterology & Hepatology
- Cleveland Clinic Foundation
- Cleveland, OH
- Representative of the American Society for Gastrointestinal Endoscopy

- John Pandolfino, MD
- Professor of Medicine
- Department of Gastroenterology
- Feinberg School of Medicine
- Northwestern University
- Chicago, IL

- Andrew Hsieh, PharmD
- Program Manager
- Medical Affairs Group
- TAP Pharmaceutical Products, Inc.
- Lake Forest, IL

- Joel E. Richter, MD, FACP, MACG
- Professor of Medicine
- Chairman, Department of Medicine
- Temple University School of Medicine
- Philadelphia, PA

- Douglas S. Levine, MD, FACG
- Executive Director, Strategic Development
- NEXIUM Development Brand Leader
- AstraZeneca LP
- Wilmington, DE

- Kathleen Lomax, MD
- Eisai, Inc.

- Byron Delemos, MD
- Associate Director, Clinical Development, Medical Affairs, Gastroenterology
- PriCara, a Unit of Ortho-McNeil Janssen Scientific Affairs, LLC

- James A. Miraldi
- President & Chief Executive Officer
- NDO Surgical
- Mansfield, MA

- Stephen Schwaitsberg, MD
- Associate Professor of Surgery
- Tufts University School of Medicine
- Director, Minimally Invasive Surgery Center
- Tufts-New England Medical Center
- Boston, MA