# Evidence Tables

Evidence Table 1. Comparative studies of medical vs. surgical management in patients with GERD

Author, Year | Intervention | | Patient characteristics | | | | Follow-up duration | Status at follow-up | | | | | | | Quality
Study design | N Enrolled/Follow-up | | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/Off all anti-secretory meds | Other med use data | QOL/Satisfaction | EMS/Others
| Gender/ Mean age
Lundell, 2001, 2000 | Omeprazole (OME) vs. open anti-reflux surgery (OAS) | | Inclusion criteria includes esophagitis; but table 2 in paper (2000) shows: | OME 20% time < 4 | ND | Yes, proven by healed esophagitis after medical treatment | 5-yr | Similar results in the 2 groups in % of pts with moderate to severe heartburn at defined time points | At 3 yr, | After 12 mos, | ND | ND | No difference in QOL assessment between 2 groups | At 5-year, % in remission (based on symptoms., PPI & surgery requirements, see paper for details): | B
RCT | OME n=154->133 (f/u) 75% M | | Grade 1 | OAS 19% time < 4 | | | 3-yr | | OME 22/133 (17%); 1 grade 3 | OME: 10% time < 4 | | | | OME 49%
| Age | | OME 6/154 (4%) | Estimated from fig. 1 in paper | | | | | OAS 16/119 (13%); no grade 3 | OAS: 4% time < 4 (normalized) | | | | OAS 68%
| <50 | 39% | OAS 10/144 (7%) | | | | | | | Estimated from fig. 1 in paper | | | | (P<0.001)
| 50–64 | 42% | Grade 0 | | | | | | | | | | | No difference in % Barrett's
| >64 | 19% | OME 96%
| OAS n=144->122 (f/u) | | OAS 93%
| Age
| <50 | 48%
| 50–65 | 38%
| >64 | 14%
Spechler, 2001, 1992 | Continuous Medical (MEDc) vs. symptomatic Medical (MEDsx) vs. open Nissen fundoplication (ONF) | | No; | % time | LES in mm Hg | ND | Mean f/u | Long term: Symptom score better in ONF group compared to MED group during the wk when meds were stopped in both groups (P0.003). | Long term: After 1 wk without meds, no significant difference in grade of esophagitis between the 2 groups. | Long term: % time pH < 4: | Long term: Off PPI: | ND | Long-term: Difference between groups on SF-36 (P&M) =NS; subscale bodily pain was better in ONF (P=0.02) | 5 pts with esophageal CA after a mean f/u of 7.1 yrs (4–12); difference between MED & ONF: NS; | B
RCT | N= 247 | | 30% with erosive esophagitis; 23% with esophageal ulcer; 40% with Barrett's | pH < 4 | MEDc 25±18 | | MED | At 1 & 2 yr, activity-index score improved in all 3 groups compared to baseline (P<0.03) | At 1 & 2 yr, grade of esophagitis improved in all 3 groups compared to baseline (P<0.03) | MED 31% (62 SD) (n=38) | MED 36% (n=89) | | Majority in both groups were satisfied with their treatments. | 4 of 5 pts with CA had Barrett's at baseline; incidence rate of esophageal CA in pts with Barrett's vs. w/o: 0.4% vs.0.07% per year.
| f/u= 208 (129 survivors; 79 deaths) | | | MEDc 20±19 | MEDsx 27±19 | | 10.6 yr | Activity index score lower in ONF than MED throughout the 2 yr f/u (P<0.003) | Grades of esophagitis lower in ONF than MED during the 2 yr f/u (P<0.003) | ONF 17% (41 SD) (n=10) | ONF 68% (n=37) | | During the 2 yr f/u, pt satisfaction: ONF>MEDc (P=0.024) & MEDsx (P=0.006). | LES higher in ONF than MED at 1 yr (significant, P value not reported).
| 98% M | | | MEDsx 23±22 | ONF 23±18 | | ONF | | | NS | P=0.002
| 58 y (25–75) | | | ONF 23±22 | | | 9.1 yr | | | At 1 & 2 yr, % time | Off any anti-reflux meds:
| MEDc n=77 | | | | | | 1992 paper: | | | pH < 4 improved in all 3 groups compared to baseline | MED 8% (n=90)
| MEDsx n=88 | | | | | | 1 & 2 yr f/u | | | (P<0.03) | ONF 38% (n=37)
| ONF n=82 | | | | | | | | | At 1 yr, duration of acid reflux by pH monitoring lower in ONF than MEDsx (P<0.03) | P<0.001
Mahon, 2005 | PPI vs. Laparoscopic Nissen fundoplication | | No; | Mean DeMeester | Mean LES in mm Hg | Dependent on PPI | 3 mos (pH, EMS study) | GI-well being score improved at 3 mos & 12 mos; more improvement in LNF by ANCOVA | ND | At 3 mos, Mean DeMeester | ND | ND | Total well-being score improved more in LNF than PPI at 12 mos (p<0.001) | LES at 3 mos | B
RCT | (LNF) | | 15% in PPI | PPI 36.9 | PPI 8.1 | | 12 mos | (p=0.010 at 3 mos; P=0.003 at 12 mos) | | PPI 17.7 | | | | PPI 7.9
| PPI 108 | | 21% in LNF | LNF 42.7 | LNF 6.3 | | | | | LNF 8.6 | | | | LNF 17.2
| LNF 109 | | | %time pH<4 | | | | | | (P <0.001, ANCOVA) | | | | (P<0.001 by ANCOVA)
| 12 mos f/u | | | PPI 9.5% | | | | | | %time pH<4
| PPI 97 | | | LNF 12.9% | | | | | | PPI 3.8%
| LNF 106 | | | | | | | | | LNF (CI 2.9–11.2) 1.4%
| 66%M in LNF | | | | | | | | | (P=0.002, ANCOVA)
| 48 yr
| 72%M in PPI
| 47 yr
Johansson, 1986 | Maintenance ranitidine for 6 mos (RAN) vs. posterior partial fundoplication (OPA) | | No; | Total reflux time= 7.7±7.3% before trial (n=28) | LES in mm Hg | Failed lifestyle modification prior to entry; half of the pts received 8 wks of ranitidine OR placebo then crossed over to other treatment; response to ranitidine not stated | 6 mos | Heartburn & regurg ↓ after 8 wks of ranitidine in RAN & OPA (P<0.01). | After 8 wks of ranitidine, significant improvement in RAN (P<0.05), not in OPA. | Total reflux time no significant ↓ after 8 wk of ranitidine (n=19). | ND | ND | All OPA pts were satisfied | LES increased to 10 ±4.6 mm in OPA (P<0.05). | C
Open label medical comparison with surgical cohort | 50% of pts received 8 wks of ranitidine before RAN or OPA (see paper) | | > grade 3 | + pH reflux test | RAN 5.6 | | | 6 mos later, no further improvement in RAN; in OPA, further improvement in heartburn, regurg & chest pain (P<0.05); all OPA pts symptom free except for 2 (mild dysphagia & chest pain) | 6 mos later, no further improvement in RAN; all OPA pts had normal mucosa (p<0.01) | After OPA (n=15), total reflux time= 0.04±0.09%, which is lower than during RAN (p<0.01) | | | (1 unable to belch).
| RAN n=16 | | RAN 6/16 (38%) | RAN 69% | (R 0–20) | | | | | Reflux was not seen in 10 subjects after OPA. | | | 5 pts in RAN dissatisfied with treatment.
| 38% M | | OPA 2/15 (13%) | OPA 67% | OPA 6.0 ± 6.7
| 60 y (35–73) | | +esophagitis | | (R 0–20)
| OPA n=15 | | RAN 15/16 | | Hernia
| 67% M | | OPA 13/15 | | RAN 100%
| 42 y (23–70) | | | | OPA 60%
Wetscher, 2001 | Continuous PPI and cisapride (MED) vs. laparoscopic anti-reflux surgery (LAS): included only if after LAS, Symptom free, no esophagitis, normal LES & pH study | | MED | Normal DeMeester score | LES in mm Hg | In MED, must respond to PPI+cisapride | MED | ND | ND | ND | ND | ND | ND | LES - see column 2 regarding LAS inclusion criterion | C
Prospective Cohort with comparison to a retrospective surgical group | MED n=83 | | Yes; only pts with mild reflux were included. | MED 16.9% | MED 6 | In LAS, 12% failed PPI treatment | 2 yr | For LAS, see column 2 | For LAS, see column 2 | For LAS, see column 2 | | | | Barrett's developed in
| 54% M | | LAS | LAS 19% | (2.5–8.0) | | LAS | | | | | | | MED 12/83
| Median age | | No; 41% with severe esophagitis | ? normal pH study as a criterion of entry in LAS | LAS 4.7 | | 3.5 yr | | | | | | | (14.5%)
| 59 y (21–74) | | | | (2.9–9.2) | | | | | | | | | LAS 0
| LAS n=42 | | | | Defective esophageal contraction waves | | | | | | | | | Pts who developed Barrett's had more defective LES & more impaired esophageal peristalsis pre-treatment (p<0.05)
| 62% M | | | | MED 0
| Median age | | | | LAS 10
| 53 y (26–67) | | | | (0–60)
Tran, 2005 | Medical (MED) vs. Fundoplication (ARS) vs. no-GERD (Ctr) | | ND | ND | ND | ND | MED | ND | ND | ND | ND | ND | ND | Esophageal CA: | C
Retrospective comparison of 3 distinct cohorts from VA hospitals | MED n=1892 | | | | | | 10.6yr | | | | | | | MED 8/20,115 patient-years (PY)
| ARS n=946 | | | | | | ARS 11.8yr | | | | | | | 40/100,000 PY
| Ctr n=5676 | | | | | | Ctr | | | | | | | ARS
| Mean age 55y | | | | | | 10.5yr | | | | | | | 8/11,156 patient-years
| 98% M; | | | | | | | | | | | | | 72/100,000 PY (MED vs. ARS, NS)
| No significant differences in all groups. | | | | | | | | | | | | | Ctr
| | | | | | | | | | | | | | 0/59,439 PY
Ye, 2001 | Unoperated GERD (NoS) vs. surgery (ARS) | | ND | ND | ND | ND | NoS f/u | ND | ND | ND | ND | ND | | Esophageal adeno-CA Incidence per 100,000 PY | C
Retrospective cohort analysis | NoS | | | | | | M 5.6 yr | | | | | | | M: 22.4 (NoS); 37 (ARS)
| n=66,965 | | | | | | F 5.7 yr | | | | | | | F: 6.6 (NoS); 0 (ARS)
| 53% M | | | | | | ARS f/u | | | | | | | Esophageal adeno-CA Standardized Incidence Ratio
| Age 60 M | | | | | | M 7.7 yr | | | | | | | M: 6.3 (NoS) (CI 4.5–8.7);
| 66 F | | | | | | F 8.0 yr | | | | | | | 14.1 (ARS)
| ARS | | | | | | | | | | | | | (CI 8.0–22.8)
| n=11,077 | | | | | | | | | | | | | F: 6.1
| 58% M | | | | | | | | | | | | | (NoS) (CI 2.9–11.2); 0
| Age 50 M | | | | | | | | | | | | | (ARS)
| 56 F
Fernando, 2002 | Medical Rx (MED) vs. laparoscopic anti-reflux surgery (LAS) | | ND | ND | ND | ND | MED | ND | ND | ND | ND | ND | Mean HRQOL better in LAS than MED (p<0.05) | ND | C
Retrospective Cohort analysis | MED n=51 | | | | | PPI use | Median f/u | | | | | | Better SF-36 in 6/8 domains in LAS than MED (p<0.05)
| -> 37 (f/u) | | | | | MED 57% | 23 mos | | | | | | Dissatisfied pts:
| 41% M | | | | | LAS 88% | LAS | | | | | | MED 22%
| Median age | | | | | P<0.05 | Median f/u | | | | | | LAS 6%
| 48 y (17–82) | | | | | H2RA use | 18 mos
| LAS n=120 | | | | | MED 28%
| -> 101 (f/u) | | | | | LAS 38%
| 50% M
| Median age
| 47 (17–80)
Holzman, 2001 | MED vs. ARS | | ND | ND | ND | ND | 1 year | ND | ND | ND | ND | 1^st^ year after ARS: | ND | ND | C
Retrospective matched cohort from Tennessee Medicaid research database | MED n=250 | | | | | | | | | | | use of GERD drugs:
| 39% M | | | | | | | | | | | ARS vs. MED,
| ARS n=135 | | | | | | | | | | | 123 days vs. 339 days
| 40% M | | | | | | | | | | | (P<0.001)
Khaitan, 2003 | MED vs. ARS | | ND | ND | ND | ND | 4 year period | ND | ND | ND | ND | % of pts using GERD drugs was in ARS than MED for each year of f/u; Year 4: | ND | Fewer GERD outpatient visits in ARS | C
Follow-up results from above study | MED n=200 | | | | | | | | | | | 74% vs. 90%;
| ARS n=111 | | | | | | | | | | | P<0.001
Isolauri, 1997 | Medical Rx (MED) vs. Nissen-Rossetti (ONF) | | Grade 3 | ND | ND | Pts failed medical & lifestyle treatments before referral for ONF | Median observation time 10.9 yr (R 9.1–13.4yr) | No or mild heartburn: | Grade 3 | ND | MED: 14/68 (21%) on PPI or H2RA regularly; | ND | ND | Barrett's baseline: | C
Retrospective Cohort | f/u 63%M | | MED 12% | | | | | MED 53% | MED 4% | | 22/68 (33%) occasionally | | | MED
| 58 yr (36–83) | | ONF 16% | | | | | ONF 84% | ONF 0% | | ONF: 2/37 (5%) on H2RA occasionally | | | 0
| MED n=81 | | Grade 2 | | | | | | Grade 2 | | | | | ONF
| -> 68 (f/u) | | MED 34% | | | | | | MED 22% | | | | | 5/39 (13%)
| ONR n=39 | | ONF 57% | | | | | | ONF 0 % | | | | | f/u
| -> 37 (f/u) | | Grade 0 | | | | | | Grade 0 | | | | | MED
| | | None | | | | | | MED 46% | | | | | 8/68 (12%)
| | | Must have erosive esophagitis to enroll. | | | | | | ONF 86% | | | | | ONF
| | | | | | | | | | | | | | 12/37(32%)
| | | | | | | | | | | | | | 1 case of esophageal adeno-CA w/o Barrett's

M: male; F: female

Evidence Table 2. Studies on endoscopic procedures

Author, Year | Study and patient characteristics | | | | | | Status at follow up | | | | | | | Quality
Study design | Intervention | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/ hiatal hernia | Responded to PPI or H2RA | Follow up duration | Change in symptoms | Esophagitis status | pH status | Off PPI / Off all anti-secretory meds | Other med use data | QOL / satisfaction | EMS / Others
| N Enrolled/ Follow up Gender/ Age
Deviere, 2005 | Enteryx(ERX) vs. Sham | Yes | Must have abnormal pH study while off PPI | Excluded hiatal hernia ≥ 5 cm | Yes | 3 mos & 6 mos | Heartburn score improved ≥ 50% more in ERX vs. Sham at 3 mos (Ratio 3.05; CI, 1.55–6.33) | ND | Difference between groups=NS; Incomplete data | At 3 mos, 68% in ERX off PPI vs. 41% in sham (ratio 1.67, CI 1.03–2.80) | At 3 mos, ≥ 50% ↓ in PPI use is 81% in ERX vs. 53% in Sham (ratio 1.52, CI 1.06-2.28) | SF-36 -P and SF-36-M improved in ERX; no significant change in sham at 3 mos. | 6/9 retreated in ERX; 20/23 sham proceeded to ERX (ratio 0.42, CI 0.22–0.73) at 3 mos. | B
RCT | 64 | | | | | | Regurg score improved ≥ 50% more in ERX vs. Sham (Ratio 2.03; CI 1.14–3.75) | | Correlation not apparent between change in total time at pH≤4 and heartburn score. | | | % change between the groups = NS, GERD-HRQL score improved by ≥ 50% significantly more in ERX at 3 months
| 61
| ERX n = 32 62% M
| 49±10 SD
| Sham n = 32 72% M
| 50±14 SD
Corley, 2003 | Radio-frequency (STR) vs. Sham | Yes | All have abnormal pH study | Median LES = 12.1 in Sham; | At least partially responsive to daily anti-acid meds | 6 & 12 mos | At 6 mos, mean heartburn score improved compared to Sham (p=0.01) | At 6 mos, no difference between groups. | At 6 mos, no difference in median acid exposure between the 2 groups. | 58% (STR) vs. 57% sham off PPI at 6 mos, p=NS | At 6 mos, daily PPI use ↓ 46% in STR vs. 29% in Sham p=NS; daily use of any meds: 61% in Sham vs. 55% in STR p=NS | At 6 mos, mean HRQL & SF-36-P improved compared to Sham (p=0.003, p=0.05) | No significant change in LES | B
RCT with X-over at 6 mos | 64 | | | 13 in STR
| 56
| STR n=35
| 46% M
| 45±12 SD
| Sham n=29
| 59% M
| 52±15 SD
Cohen, 2005; Included pts from Johnson, 2003 (UI14499767) & Johnson, 2003 (UI 12591037) | ERX | Included 1 pt with > grade 3 | Must have abnormal pH study | Included 12 with hiatal hernia ≥ 3 cm | Yes | Up to 24 mos | Heartburn score improved median 80% (CI 71%, 87%) compared to baseline off PPI. | At 12 mos, unchanged in 59/107 (55%), improved in 14 (13%), ↑ in severity in 34 (32%)at 12 mos. | 38/102 (37%) normalized at 12 mos (CI 28%, 47%). | 43/64 (67%) off PPI at 24 mos (CI 54–78%). | 46/64 (72%) ≥ 50% ↓ in PPI use at 24 mos (CI 59–82%) | Improved GERD-HRQL in 78% (CI 69%, 85%) & SF-36-P 12% (CI 7.4%, 17%); | No significant change in EMS data at 12 mos. | B
Prospective Cohort | 144 | | | | | | Regurg score improved median 88% (CI 79%, 92%) at 24 mos. | | | | | no change for SF-36–M
| 64
| 61%M
| Mean age 48 (12 SD)
Deviere, 2002 | ERX | Yes | Must have abnormal pH study | Excluded hiatal hernia ≥ 3 cm; Excluded esophageal motility disorder other than associated with GERD | Yes | 1 mos; 4–12 mos | Heartburn score improved at 1 month (p=0.038). | ND | ND | ND | 4 patients resumed PPI at follow up (4–12 mos). | ND | LES=16.7 at 6-month (p=0.038 compared to baseline) | C
Cohort, pilot study | 15
| 15
| Mean age 52
Schumacher, 2005 | ERX | Yes | Must have abnormal pH study | Median LES = 10 mm Hg; Excluded hiatal hernia ≥ 3 cm | Yes | 12 mos | Heartburn & regurg scores improved compared to off PPI levels (p<0.0001) & improved after treatment to a level similar to on PPI | No change in 55%; | 28/54 (52%) normalized | 65% off PPI at 12 mos; | 86% ≥ 50% PPI ↓ dosage at 12 mos (CI 77–93%) | SF-36-P &-SF-36-M improved compared to off PPI levels (p<0.0001 & p=0.0012), GERD-HRQL improved compared to off PPI levels | Median LES = 9 mm (NS); | B
Prospective Cohort | 93 | | | | | | | improved in 12%; | | | | | 6 pts retreated between months 1 & 3.
| 76 | | | | | | | worsened in 33%
| 68%M
| Mean age 48 (14 SD)
Filipi, 2001 | Endocinch (ECH): | Yes | Must have abnormal pH study while off meds; mean % time ≤ 4 = 0.63 (64 pts) | Mean LES= 16.1 mm Hg; Excluded hiatal hernia > 2 cm | Yes; responded to PPI, H2RA or antacids | Up to 6 mos | Heartburn & regurg score improved from baseline at 3 & 6 mos (p=0.0001) | No significant change in mean esophagitis grade | Mean % time ≤ 4 = 8.5 at 6- mos in 29 pts (p=0.011 compared to baseline) | 62% of patients taking PPIs, H2RAs, antacids or prokinetics at baseline taking fewer than 4 doses of medication per month at 6 mos | ND | SF-36-P and SF-36-M, no significant change; significant change in 2 subscales. | LES=20.6 mm Hg at 6-month (no significant change); plication configuration did not affect Symptom or pH results. | C
RCT | Linear vs. circumferential plication
| 64 (52% in linear group)
| 51
| 70%M
| Mean age 46
Chadalavada, 2004 | ECH vs. laparoscopic surgery (LAS) | Excluded erosive esophagitis in ECH; not in LAS | Abnormal pH: 16% in ECH vs. 18% in LAS | Excluded >2 cm hiatal hernia in ECH; not in LAS | No; had heartburn not responsive to med Rx | Mean 7 mos (ECH) | ND | ND | ND | In ECH: 25% off an antisecretory med | PPI/motility drug use: 32% in ECH vs. 13% in LAS (p=0.03) | Satisfied: 66% in ECH; 93% in LAS (NS) | 3 ECH pts had LAS within 6 mos of ECH | C
Non-randomized comparison | ECH n=47->44 (f/u) 32% M 47±2 SEM | | | | | Mean 8 mos (LAS)
| LAS n=40–>40 (f/u) 30% M 44±2 SEM
Velanovich, 2002 | ECH vs. lap surgery (LAS) | ND | Abnormal reflux on pH study in ECH | Excluded >2 cm hiatal hernia in ECH | ND | 2mos, | See QOL column | ND | ND | ND | ND | GERD-HRQL improved in both groups (p<0.00001); difference between groups=NS; Satisfied: 78% in ECH; 98% in LAS (p<0.01) | ND | C
Case-control comparison, matched for gender, age & pre GERD-HRQL score | ECH n=27->27 (f/u) 33% M 47±4 SD
| LAS n=27->27 (f/u) no actual data on age
Abou-Rebyeh, 2005 | ECH | Yes | All have abnormal pH study while off medical therapy | ND | Yes | 12 mos | 39% improvement in heartburn, 14% free of heartburn | Esophagitis present in | Significant reduction in pathologic reflux in 84% after 2 mos and 66% after 1 yr; normalization in 24% after 2 mos and 14% after 1 yr | 20% off PPI after 1 yr | PPI reduced from 6.5 to 1.9 days a week after 2 mos but increased to 4.3 days per week after 1 yr | ND | 74% of sutures totally lost and 16% lose after 1 year, None had correct placement of initial sutures; EG had no effect on esophageal peristalsis or LES pressure | C
Prospective Cohort | 38 unclear f/u N | | | | | | | Baseline 41% | | | 63% reduced dose at 1 yr
| 55%M 55 ± 10) | | | | | | | 2 mos 31%
| | | | | | | | 12 mos, 56%
Arts, 2005 | ECH | Yes | All have abnormal pH study while off medical therapy | Excluded > 3 cm hiatal hernia | Failed or partial response | 12 mos | Improved Symptom score at 12 mos (p<0.05 compared to before Rx, off PPI) | One healed at 12 mos. | 6/20 (30%) normalized pH | 6/20 (30%) off PPI (p<0.01) | 6/20 (25%) now responds to dose that failed before Rx | ND | 11 patients underwent 2^nd^ Endocinch | C
Prospective Cohort | 20 | | | | | | | 3 of 4 had same grade at 12 mos.
| 20
| 50%M
| 45 ± 11 SD
Chen, 2005 | ECH | No; | All have abnormal pH study | Median LES= 17.6 mm; 9 had ≥ 2 cm hiatal hernia | Dependency on anti-secretory meds. | Up to 24 mos | ~50% no heartburn & 69% no regurg at 24 mos (p<0.0001) | ND | 27/68 (39.7%) normalized at 3–6 mos | 30/74 (41%) off PPI at 24 mos. | 21/74 (28%) ≥ 50% PPI ↓ dosage at 24 mos (p=0.0011). | ND | Median LES=17.1(NS); ↑ in residual LES (p=0.017); 2 had Nissen 2° to poor response | C
Prospective Cohort | 85 | 10 had grade 3
| 81
| 44%M
| 48 (15 SD)
Mahmood, 2003 | ECH | Excluded patients with an esophageal stricture or Barrett's esophagus | All have abnormal pH study while off medical therapy | Mean LES= 10.78 mm Hg; Excluded > 2 cm hiatal hernia | Many pts with breakthrough symptom while on PPIs | 12 mos | Heartburn (p<0.0001) & regurg scores (p<0.001) improved at 12 mos | Esophagitis not worsened at 3 mos. | At 3 mos, DeMeester improved (p=0.028); total time pH<4, change=NS | 64% off PPI at 12 months | 36% need < 4 doses of PPI/month at 12 mos (p ≤ 0.001) | QOL improved at 12 mos (p ≤ 0.01) | At 3 mos, Mean LES=10.84 mm (NS) | C
Prospective Cohort | 26
| 22
| 13/22(59%M)
| Mean age
| 39 yr
| (R 22–62)
Schiefke, 2005 | ECH | No; 2/70 (2.9%) ≥ grade 3 | All have abnormal pH study | LES= 7.mm; Excluded > 3 cm hiatal hernia | At least partial response to PPI | 18 mos | Heartburn score improved (p=0.001) | No change: 40/70(57%); | 16/54 (28%) normalized at 12 mos | 4/70(6%) off PPI at 18 mos | > 50% PPI ↓ dosage: 47% at 6 mos; then 24% at 18 mos | 14/70 considered responders based on pt satisfaction, heartburn & >50%↓ dose. | LES 10.3(NS); All sutures retained in only 12/70 (17%) of patients;no sutures in 18/70 (26%) | C
Prospective Cohort | 70 | | | | | | | Improved: 20/70(29%);
| 70 | | | | | | | Worsened: 10/70 (14%)
| 62%M
| Median age 48 y
| 48 y
| (R 22–77)
Tam, 2004 | ECH | 4 pts with grade A, 1 with grade B; excluded grade D pts | All have abnormal pH study | Mean fasting LES = 6.7 mm Hg; Post-prandial LES = 4.3 mm; Excluded > 2 cm hiatal hernia | Dependent on PPI or H2RA | 6 mos, 12 mos | See QOL column | 3 of 5 had same grade; 2 resolved; 2 new cases of grade A | 4/15 (27%) normalized at 6 mos. | 7/14 (50%) off PPI at 12 mos | 8/15 (53%) at ↓ med dose at 6 mos | GERD-HRQL improved at 12 mos (P<0.05); SF-36-P ↑ at 12 mos (p<0.05); no significant Δ for -M | Mean fasting = 5.0 mm (NS); post-prandial = 6.2 mm(p<0.05); ↓ tLESRs (p<0.05) | C
Prospective Cohort | 15
| 14
| 47%M
| Median age
| 46 yr
| (R 24–64)
Go, 2004 | Stretta (STR) | ND | ND ?at least some had pH study | Excluded hiatal hernia | All on PPI | 10 mos (R 3–32 mos) | Mean heartburn score improved (p=0.0012) | ND | ND | 29% off PPI | ND | GERD-HRQL symptom satisfaction score improved (p=0.0001) | 10 pts failed previous anti-reflux surgery; symptom satisfaction score improved in this group (p=0.0166); | C
Prospective Cohort | Only > 3 mos f/u data were used in this study | | | | | | | | | | | | 4 pts had fundoplication after Stretta.
| 50
| 44% M
| 47 yr
| (R 22–74)
| 37 (f/u)
Lutfi, 2005 | STR | Yes | All have abnormal pH study | Excluded if LES < 8mm; excluded if hiatal hernia > 3 cm | All on PPI | 26 mos (R 6–36 mos) | See QOL column | ND | 24 had pH data at f/u: | 26/61 (43%) off PPI | 13/61 (21%) ≥ 50% PPI ↓ dosage | QOLRAD improved (p<0.001) | 8 pts had Nissen after Stretta | C
Prospective Cohort (includes patients from “Vanderbilt database”: Houston, 2003, Torquati, 2004, Richards 2003, Richards 2001) | 85 had STR; only pts with f/u > 6 mos qualified for this study: 77 | | | | | | | | 10/24 (42%) normalized pH (all in off PPI & ≥ 50% PPI ↓ group)
| 61 completed survey
| 39% M
| 52 yr (R20–82)
Richards, 2003 | STR vs. laparoscopic fundoplication (LAS) | Some had esophagitis, actual data not reported | Acid exposure % time: | STR - LES= 25.4 mm; excluded hiatal hernia > 2 cm; | ND | Mean f/u 7.3 mos (STR); 5.2 mos (LAS) | At 6 mos, GERD Symptom improved similarly in both groups (NS). | ND | At 7.2 mos, STR - 8/22 (36%) normal acid exposure; ND on LAS group | STR- 58% off PPI; | STR - 31% ↓ PPI dose | At 6 mos, GERD-QOL & SF-12 improved in both groups (p<0.01) compared to baseline on- meds. | No significant change in mean LES in STR; ND in LAS | C
Non-randomized comparison (Based on “Vanderbilt database”) | STR n=65 42% M | | STR - 11.3% | LAS - LES= 18.2 mm (p<0.01); included hiatal hernia > 2 cm | | | | | | LAS - 97% off PPI
| 46±12 SEM | | LAS - 8.5%
| LAS n=75 44% M | | (p<0.01)
| 49±14 SEM
Tam et al, 2003 | STR | 2 Los Angeles grade A, 2 grade B, 1 grade C; Excluded pts with grade D | Mean DeMeester = 38.8 | mean post-prandial basal LES=5.2 mm; Excluded >2 cm hiatal hernia | Dependent on daily acid suppressant | Up to 12 mos | See QOL column | 10 grade A at 6 mos | 4/20 (25%) had normal acid exposure at 12 mos; mean DeMeester = 24.1 (p<0.05). | 13/20 (65%) off PPI at 12 mos | At 6 mos, 15/20 off PPI, 3 of remaining 5 on ↓ dose of PPI | GERD-HRQL, SF-36-P & SF-36-M improved at 12 mos (p<0.05) | At 6 mos, mean post-prandial basal LES=8 mm (p<0.01); ↓ TLESR (p<0.01) | C
Prospective Cohort | 20
| 19
| 50%M
| Median age 51
| (R 32–69)
Triadafilopoulos, 2002 & 2001 Included 9 pts from DiBaise, 2002 | STR | Yes | All have abnormal pH study; median DeMeester off meds = 40 | Median LES =15 mm Hg; Excluded >2 cm hiatal hernia | At least partial response to meds | Up to 12 mos | Heartburn score improved compared to baseline off med (p=0.0001) | Esophagitis (grades 1 or 2) present in 31% pre- and 25% post-Rx at 6 mos (NS) | DeMeester = 26.3 (p=0.0001) at 6 mos | At baseline, 88% on PPI, at 12 mos, 30% on PPI (p<0.0001); 40% off all meds | ND | GERD-HRQL improved at 12 mos compared to baseline on meds (p=0.0007); SF-36-P &-M improved (p<0.0001) | At 6 mos, median LES=12.6 (p=0.007) | C
Prospective Cohort | 118
| 94
| 61%M
| Mean age 47
| (12 SD)
Triadafilopoulos, 2004 | STR responder vs. non-responder | Responder: | | | | | 1. GERD-HRQL, satisfaction score, PPI responder subgroups improved in distal esophageal acid exposure time (p<0.001); nonresponders: change NS | | | | | | | C
Post hoc analysis of data from Triadafilopoulos, 2002 & 2001 | 118 | GERD-HRQL ≤ 10, heartburn severity score ≤ 1, no daily PPI or pt satisfaction score >4 | | | | | 2. Heartburn responder subgroup improved in distal esophageal acid exposure time from a baseline of 7.8% to 4.1% (p<0.001); nonresponders: 11.2% to 8% (p=0.04)
| 61%M | Nonresponder: | | | | | 3. Changes in heartburn correlated with changes in esophageal acid exposure(r=0.26, p=0.01)
| Mean age 47 | GERD-HRQL > 10, heartburn severity score > 1, daily PPI or pt satisfaction score ≤4 | | | | | 4. Changes in satisfaction negatively correlated with changes in esophageal acid exposure (r= -0.23, p=0.02).
| (R 22–75)
Wolfsen, 2002 | STR | ND | ND | ND | At least partial response to meds | Mean follow up = 8 mos | Satisfactory Symptom control: 26.3% at baseline on drugs compared to 77% after RF | ND | ND | At baseline, 70.6% pts on PPI twice daily, after RF, 51% required no antisecretory meds. | ND | ND | ND | C
Survey | 558 from 33 institutions
Pleskow, 2005, 2004 | Endoscopic Plication System | Yes | All have abnormal pH study; mean DeMeester = 48.7 | LES ≥ 5mm Hg; excluded hiatal hernia > 2 cm | Dependent on antisecretory meds | 12 mos | Median Symptom scale improved from baseline off med (p<0.0001); no change compared to baseline on med | ND | At 6 mos, mean DeMeester = 34.5; 30% normal pH score | 36/53 (68%) off PPI at 12 mos (baseline 53/57 on PPI); 13/57 (23%) off all antisecretory meds | ND | Median GERD-HRQL improved compared to baseline on & off meds (p=0.0237, p<0.0001) | No significant change in EMS data (from 2004 paper) | B
Prospective Cohort | 64
| 57
| 48%M
| 46 (13 SD)

Evidence Table 3. Systematic Reviews and meta-analyses

Author, year | Question | | | Database searched, year | Type of studies included (# studies) | Population | Intervention / Duration | Comparison group | Outcomes | Med vs. Med^1^ | Med vs. Placebo^2^ | Med vs. Med^2^ | Med vs. Surg | Surg vs. Surg | Endo vs. Sham/ Surg
Quality | Q1 | Q2 | Q3
Caro, 2001 | X | | | MEDLINE, Jun 1979- Jun 2000 | RCTs (acute treatment: 26; maintenance treatment: 15) | endoscopically confirmed GERD for acute treatment; endoscopically confirmed healing of esophagitis for enrollment in the maintenance phase | PPI | PPI (omeprazole) or H2RA (ranitidine) | acute treatment: symptom relief; esophageal ulcer healing (endoscopically confirmed) | X | | X
B | | | | | | | Duration: (acute treatment): 4–8 wk | | maintenance treatment: relapse rate (endoscopically confirmed)
| | | | | | | Follow-up (maintenance treatment): 6–12 mo | | No significant difference between PPIs
| | | | | | | | | Results favored PPI when compared to H2RAblocker
McDonagh, 2004 | X | | X | MEDLINE, 1966-Nov 2003 | RCTs (for PPI vs. PPI, acute treatment: 16; maintenance treatment: 4) (for PPI vs. H2RAblocker, acute treatment: 22; maintenance treatment: 1) | adults outpatients with symptoms of GERD; also adults with peptic ulcer or NSAIDs induced ulcer were analyzed separately | PPI | PPI, H2RA, prokinetics, antacids | for acute treatment: symptom relief; healed esophagitis (endoscopically proved) | X | | X
Oregon Report | | | | EMBASE, 1980-2003 | | | Duration: (acute treatment): 8 wk | | for maintenance treatment: relapse of symptoms; esophagitis relapse
A | | | | Cochrane, 3/2003 | | | Follow-up (maintenance treatment): 4 wk to 5 yr
Carlsson, 1997 | | X | | ND | Individual Patient Data Meta-analysis based on 5 RCTs published between 1989-1995 | endoscopically proven esophagitis healed; complete symptom resolution or mild residual symptoms at admission to maintenance phase | PPI (omeprazole) | placebo or PPI (omeprazole) or H2RA (ranitidine) | endoscopic remission | | X | X
B | | | | | | | Follow-up (maintenance treatment): 6–12 mo | | Results favored PPI (omeprazole 10 or 20 mg daily)
| | | | | | | | | Meta-regression: prognostic factors for the risk of relapseincluded pre-treatment severity of esophagitis or regurgitation, age, and smoking
Donnellan, 2005 (Cochrane Database Systamtic Review) | X | | X | MEDLINE, 1966-2003 | RCTs: 51 | reflux esophagitis healed (endoscopically proved) or ENRD with main presenting symptoms heartburn and /or acid reflux | PPI; H2RA; prokinetics; sucralfate; or compbinations | placebo or PPI, H2RAblocker, prokinetics, sucralfate | for reflux esophagitis: proportion of relapse; proportion of symptom relapse | | X | X
A | | | | EMBASE, 1980-2003 | | | Follow-up (maintenance treatment): up to 12 mo | | for ENRD: proportion of symptom relapse
| | | | Cochrane, 2/2003 | | | | | Results favored PPI
| | | | CINAHL, 1982-2003 National Research Register, 2/2003
Corey, 2003 | X | | | MEDLINE, 1966-Oct 2001 | RCTs: 9; Cohorts: 25 | BE by histologic confirmation | Surgery (not specified) | medical treatment (not specified, PPI??) | incidence of adenocarcinoma by histologic confirmation | | | | X
C | | | | | | | Follow-up: ≥12 mo | | no difference between medical and surgical groups
Catarci, 2004 | | | X | MEDLINE, 1966-2002 | RCTs (lap vs. open fundoplication: 6; partial vs. total wrap: 9) | GERD (not specified) | laparoscopic fundoplication | open fundoplication | perioperative mortality was 0 for all procedures | | | | | X
A | | | | EMBASE, 1980-2002 | | | partial wrap | total wrap | [underlined: lap vs. open fundoplication]
| | | | HealthSTAR, 1975-2002 | | | division of short gastric vessels | | short-term outcomes: significantly lower operative morbidity rate, shorter postoperative stay, and shorter sick leave for lap vs. open fundoplication
| | | | Cochrane, 2/2002 | | | Follow-up: 3 mo to >8 yr | | midterm /long-term follow-up: no significant differences were found regarding the incidence of recurrence, dysphagia, bloating, and reoperation for failure
| | | | | | | | | [underlined: partial vs. total wrap]
| | | | | | | | | short-term outcomes: no significant differences in operative morbidity, and in operative time
| | | | | | | | | midterm /long-term follow-up: significantly lower incidence reoperation for failure after partial fundoplication; no significant differences regarding the incidence of recurrence and /or dysphagia

1 Acute treatment (duration: 4–8 weeks)

2 Maintenance treatment (duration ≥ 6 mo)

Evidence Table 4. RCTs on surgical interventions

Author, Yr | Intervention | Patient characteristics | | | | Follow up duration (yr) | Status at follow up (P-value compared to preoperative values) | | | | | | | Quality
Study design | Enrolled/ Final Other characteristics | % ≥ grade 3 esophagitis | pH status | EMS / hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ Others
Ludemann, 2005 | Laparoscopic total fundoplication | 24% Barretts/stricture | Abnormal mean score (performed in 34 patients) | LES:24% abnormal | ND | 5 | Heartburn: 90% improved | ND | ND | 94% off PPI | ND | 78% excellent or good global outcome | ND | B
| Enrol/Final: 53/51 | | | | | | | | | | | 88% good QOL
| Age:50 yr for men and 57 for women (whole group)
| Gender: 35% men
| Setting: University hospital
| Country: Australia
| Laparoscopic Partial fundoplication | 21% Barretts/stricture | Abnormal mean score (performed in 35 patients) | LES: 20% abnormal | ND | 5 | Heartburn: 80% improved | ND | ND | 98% off PPI | ND | 86% excellent or good global outcome | ND
| Enrol/Final: 54/50 | | | | | | | | | | | 98% good QOL | Men were younger than women in the whole group
Hagedorn/Lundell | Open total fundoplication | 28% (whole group) | Abnormal mean score | 7% abnormal | nd | 11.5 | Heartburn 90% | ND | ND | ND | ND | ND | ND | B
| Enrol/Final: 65/nd (110 for the whole group) | | | | | | Regurgitation 91%
| Age:53 (25–74) for the whole group
| Gender: 38% men for the whole group
| Setting:University hospital
| Country: Sweden
| Open partial fundoplication | | Abnormal mean score | 6% abnormal | | | Heartburn 90% | ND | ND | ND | ND | ND | ND
| Enrol/Final: 72/nd (110 for the whole group) | | | | | | Regurgitation 91%
Nilsson, 2004 | Laparoscopic total fundoplication | 1 patient Barrretts | Abnormal mean score | Abnormal mean score | 0% PPI | 5 | 100% | | Normal level | 94% | ND | PGWB Improved | Increased and stable | B
| Enrol/Final: 30/17) | | | | | | | | Sig compared to baseline; but no differences between surgeries | | | P<0.001 | NS
| Age:53 (25–74) for the whole group
| Gender: 38% men for the whole group
| Setting:University hospital
| Country: Sweden
| Open total fundoplication | 4 patients Barretts | Abnormal mean score | Abnormal mean score | 0% PPI | | 92% | | Normal level | 74% | ND | PGWB Improved | Increased and stable
| Enrol/Final: 30/24 | | | | | | | | Sig compared to baseline; but no differences between surgeries | | | P<0.001 | NS
O'Boyle, 2002 | Laparoscopic total fundoplication with division of gastric vessels | 19% Barretts or stricture | 10.3% and only 50% underwent | Abnormal Mean pressure | Total n unclear on multiple meds | 5 | Heartburn 88% | ND | ND | 91% | ND | 70% good QOL | ND | B
| Enrol/Final: 52/50 | | | 56% hiatus hernia | | | Regurgitation 90%
| Age:47
| Gender: 60% men for the whole group
| Setting:University hospital
| Country: Australia
| Laparoscopic total fundoplication without division of gastric vessels | 24% Barretts or stricture | 10.3% and only 50% underwent | Abnormal Mean pressure | Total n unclear on multiple meds | 5 | Heartburn 82% | | ND | 91% | ND | 76% good QOL | ND
| Enrol/Final: 50/49 | | | 53% hiatus hernia | | | Regurgitation 96%
| Age:47
| Gender: 60%

Evidence Table 5. Non-randomized comparative studies on surgical interventions

Author, Yr | Intervention | Patient characteristics | | | | Follow up duration (yr) | Status at follow up (P-value compared to preoperative values) | | | | | | | Quality
Study design | Enrolled/ Final Other characteristics | % ≥ grade 3 esophagitis | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all antisecretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ Others
Kamolz, 2002 | Laparoscopic Nissen fundoplication | 69% for both groups | Mean DeMeester score abnormal | Abnormal mean score % data ND | 0% | 5 | 100% improved | ND | Normal mean DeMeester score | 100% (antireflux meds) | NA | Mean score comparable to healthy | Mean LES score normal % data ND | B
UI | Enrol/final: 104/69 | | | | | | | | | | | Patient satisfaction 98%
12430078 | Age: 52.1±9.8 (both groups)
Prospective | Gender: Male 55% (both groups)
| Country: Austria
| Setting: University hospital
| Laparoscopic Toupet fundoplication | | Mean DeMeester score abnormal | Abnormal mean score % data ND | 0% | 5 | 93% improved | ND | Normal mean DeMeester score | 97% (antireflux meds) | ND | Mean score comparable to healthy Patient satisfaction: 96.9% | Mean LES score normal % data ND
| Enrol/final: 65/33)
Granderath, 2002 | Laparoscopic Nissen fundoplication | ND | Abnormal mean DeMeester score | Mean score abnormal | 0% PPI | 5 | Heartburn: 97.2% | ND | Mean score normal range % data ND | ND | ND | ND | Mean score normal range % data ND | C
11997816 | Enrol/final: 345/64 | | | | | | Regurgitation: 91.2% (data presented for both groups)
Prospective | Age: 49.2 (29–79) whole group
| Gender: 58% (whole group)
| Country: Austria
| Setting: University hospital
| Laparoscopic Toupet fundoplication | ND | Abnormal mean DeMeester score | Mean score abnormal with weak peristalsis | 0% PPI | 5 | | ND | Mean score normal range % data ND | ND | ND | ND | Mean score normal range % data ND
| Enrol/final: 155/39 | | | | | | | | | | | | Patients with poor esophageal motility underwent Partial fundo
Pelgrims, 2001 | Open Nissen fundoplication | 18% | 5 patients underwent and all abnormal | Normal LES score | 0% | 6 | 91.8% improved | ND | ND | 85% off all meds | ND | ND | ND | C
Retrospective analysis | Enrol/final: 61/nd | 3.5% had Barrett's | | 81% hiatal hernia | All patients had recurrent symptoms after withdrawal of meds
| Age: 55 (28–76)
| Gender: 66%
| Country: Belgium
| Setting: University hospital
| Laparoscopic Nissen fundoplication | 18% | 77 patients underwent and all abnormal | Normal LES score | 0% | 4 | 94% | ND | ND | 88% off all meds | ND | ND | The records indicate the open procedure was abandoned after the year 1994
| Enrol/final: 149/nd | 5% had Barrett's | | 90% hiatal hernia
| Age: 47.5 (24–81)
| Gender: 58%
Patti, 2003 | Laparoscopic total fundoplication | Barrett's 16% | Abnormal mean score | Normal peristalsis | ND | 5.5 | 85% | ND on Barrett's | 72% | 92% (off PPI) | ND | ND | Mean LES pressure normal range 20% follow-up for objective tests | C
Retrospective analysis | Enrol/final: 94/94 | | | Hiatal hernia: 62%
| Age: 55±15 (15–93) whole group
| Gender: 55% Males (whole group)
| Country: USA
| Setting: University hospital
| Laparoscopic partial fundoplication | Barrett's 19% | Abnormal mean score | Weak peristalsis | ND | 5.9 | 67% | ND on Barrett's | 44% | 75% (off PPI) | ND | ND | Mean LES pressure normal range
| Enrol/final: 141/141 | | Difference BW: P=0.01 | Hiatal hernia: 74% | | | | | | | | | 34% follow-up for objective tests

Evidence Table 6. Cohorts (non-comparative) studies on surgical interventions

Author, Yr | Intervention Enrolled/Final | Patient characteristics | | | | Follow up /duration (yr) | Status at follow up (P-value compared to preoperative values) | | | | | | | Quality
Study design | Population and study characteristics | % ≥ grade 3 esophagitis | pH status | EMS /hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/Others
Anvari, 2001 | Laparoscopic Nissen Fundoplication | ND | Mean acid reflux (%)8.43±0.53 | Lower esophageal sphincter: abnormal 7.16±0.33 | 36% | 5 | Improved GERD symptom score | ND | Reduced | 88% | ND | Satisfaction: 86% | Lower esophageal sphincter: normal range P<0.001 | B
Prospective Cohort | Enrol/Final: 332/ 181 | | abnormal | Hiatal hernia: ND | | | P<0.0001 | | P<0.0001 | | | Re-surgery Acceptance: 89% | Tightness of wrap varied with pre-op Lower esophageal sphincter
| Age: 46.5±14.1
| Gender: Male 38%
| Country: Canada
| Setting: University Hospital
Booth, 2002 | Laparoscopic Nissen Fundoplication | 20% (> grade 2) | 5% abnormal | ND | ND | 8 | Heart Burn: Improved 93% | ND | ND | 86% | ND | Satisfaction: 91% | ND | C
Prospective Cohort | Enrol/Final: 179/48 | | | | | | Regurg: Improved 91%
| Age: 41 median (9–82)
| Gender: Male 66%
| Country: UK
| Setting: Hospital
Lafullarde, 2001 | Laparoscopic Nissen Fundoplication | ND | ND | ND | ND | 6 | No reflux symptoms: 87% | ND | ND | 89% | ND | High mean score for satisfaction | ND | C
Prospective Cohort | Enrol/Final: 178/176 | | | | | | | | | | | Re-surgery acceptance: 90%
| Age: nd
| Gender: nd
| Country: Australia
| Setting: University Hospital
Bammer, 2001 | Laparoscopic Nissen Fundoplication | ND | Mean score abnormal | Mean score abnormal | ND | 6.4 | Heartburn: 5.8% | ND | ND | 86% | ND | Overall well being score improved P <0.0001 | 12.7% had barretts before surgery and none reported development of dysplasia/adenocarcinoma | C
Retrospective Cohort | Enrol/Final: 171/171 | | | | | | Regurg: Improved 93.6% | | | | | Satisfaction: 93%
| Age: 52±14
| Gender: Male 63%
| Country: US
| Setting: Hospital
Granderath, 2002 | Laparoscopic Toupet Fundoplication | 33.6% | 100% abnormal | Lower esophageal sphincter: abnormal 100% | 0% | 5 | Heartburn: Improved 97.4% | ND | 4.50% | 97.40% | ND | Improved to normative healthy data | ND | C
11918872 | Enrol/Final: 155/39 | | | | | | Regurg: Improved 96.7%
Prospective Cohort | Age: 50.2 (29–74)
| Gender: Male 59%
| Country: Austria
| Setting: University hospital
Kamolz, 2002 | Laparoscopic antireflux procedures (excluded redo-surgery) | ND | Abnormal mean DeMeester score 100% | ND | 0% | 5 | ND | ND | ND | ND | ND | Mean score comparable to healthy (NA compared to PPI at 5 yr) | ND | C
UI | Enrol/Final: 511/107 | | | | | | | | | | | Difference sig compared to untreated patients
12236479 | Age: 47.6 (28–79)
| Gender: 55%
| Country: Spain
| Setting: University hospital
Franzen, 1999 | Posterior Partial Fundoplication | 25% | 70% abnormal | 99% abnormal | ND | 10 | Clinically improved 92% | ND | 24% pathological reflux | 94% | ND | ND | ND
Prospective Cohort | Enrol/Final: 101/87 | | | | 100% on meds for 6 mo | | | | | | | | 11% had dysphagia compared to 66% preop
| Age: ~57(70 yrs; 53; 53; 63) grade1–4 esophagitis | | | | | | | | | | | | 2% new dysphagia
| Gender: Male 52% | | | | | | | | | | | | Useful surgical procedure except in severe esophagitis
| Country: Sweden
| Setting: University Hospital
Henderson, 1985 | Open Total Nissen Fundoplication | 51% | 91.9% + ve status | Lower esophageal sphincter: abnormal 46.2% | ND | 6.5 | 93.1% excellent results | ND | ND | ND | ND | ND | ND | C
Prospective Cohort | Enrol/Final: 351/335 | | | Hiatal hernia: 68.9%
| Age: 45.5 (17–75)
| Gender: 35%
| Country: Canada
| Setting: University hospital
Grande, 1994 | Open Total Nissen Fundoplication | 32% | ND | ND | 0% | 20 | 85% grade 1 and 2 score | ND | ND | 85% of meds | ND | 89% satisfied and willing for re-surgery | 92% success rate in controlling symptoms over the 20yr period from actuarial analysis | B
Prospective Cohort | Enrol/Final: 160/157 | | (not taken into account for surgery) | (not taken into account for surgery)
| Age: 53±4
| Gender: 55%
| Country: Spain
| Setting: University hospital
Luostarinen, 1993 | Open Total Nissen Fundoplication | 69% | ND | ND | ND | ~6 | 70% | ND | pH status 71% improved | ND | ND | ND | ND | C
| Enrol/Final: 127/72
| Age: 48 (22–74)
| Gender: 57% men
| Country: Finland
| Setting: University hospital

Evidence Table 7a. Age as modifying factor for outcomes after laparoscopic fundoplication

Author Yr | Pre-operative variable assessed | Intervention | Baseline patient characteristics | | | | | Follow-up duration | Status at follow up | | | | | | | Quality
Country | Age | Enrolled/Final | Sex | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | Responded to PPI or H2RA | EMS/Hiatal hernia | | Change in symptoms | Esophagitis status | pH status | Off PPI/Off all anti-secretory meds | PPI dose or now responds to dose that failed before Rx | QOL/satisfaction | EMS/others
Setting
Study design
Khajanchee 2002 | 71 | Nissen 90% | 57% male | 23% Stricture | Abnl | Non-responsive | 7.6±7.4 LES mmHg | 22 mo | No difference between groups for heartburn, dysphagia, cough, regurgitation, chest pain | ND | No difference between groups for DeMeester scores | No | 2 (7%) intermittent meds | No difference between groups for time to normal activities; | No difference between groups for LES | C
USA | | Nissen/Collis 3% | | 23% Barrett's | 84±58 | | 17% Impaired motility | | | | | | | No difference between groups for SF-36 HRQOL (elderly n=7 vs non-elderly n=8)
Private center | | Toupet 7%
Ambi-directional case-matched control | | 30/30
| 44 | Nissen 97% | 53% male | 17% Stricture | Abnl 88±57 | | 7.0±4.0 LES mmHg | 19 mo | | | | No | 2 (7%) intermittent meds
| | Toupet 3% | | 17% Barrett's | DeMeester | | 7% Impaired motility
| | 30/30 | | | | | Type II hiatal hernia excluded
Brunt 1999 | 69 (65–82) | Nissen 97% | 42% male | ND | ND | ND | 8.3±6.3 LES mmHg | 27 mo (med) | No difference between groups for heartburn, dysphagia, regutgitation, epigastric/substernal pain | ND | ND | 94% | ND | No difference between groups for time to normal activities | ND | C
USA | | Toupet 3% | | | | | 1 (3%) dysmotility
University hospital | | 36/36
Prospective cohort
| 44 (18–64) | Nissen 90% | 56% male | | | ND | 8.4±6.0 LES mmHg | | | | | ND
| | Toupet 10% | | | | | 31 (10%) dysmotility
| | 303/303
Stewart 2004 | 44 | Anterior | 61% male | ND | ND | ND | ND | 3.7 | No association between symptom level and age | ND | ND | Use of PPI, antacids, & H2RA correlate to DeMeester score p<0.001 | ND | 68%–77% reported excellent or good results, 7% reported poor results | ND | C
UK | | partial 55% | | | | | | 2.3
Hospital | | Nissen 27% | | | | | | 3.5 yr (med)
Ambi-directional cohort | | Open Nissen 17%
| | 357 (questionnaire)
Jackson 2001 | ≤50 yr 44(54%) | Nissen 95% | 54% male | 62% esophagitis | 93% abnl | 21% with partial or no response to PPI | 65% hiatal hernia | 15 mo | Good response by Visick score 91%, 9% reported poor response, findings confirmed by GERD-HRQL; ≤50 yr predictive of good outcomes p<0.021 | ND | ND | ND | ND | 12 days to work, 37 days to full physical activity | ND | C
USA | >50 yr 37(46%) | Toupet 5% | | 22% Barrett's | DeMeester
University hospital | | 100/81
Prospective cohort
Power 2004 | 43 | Nissen | 47% male | 48% esophagitis | 40 DeMeester | ND | ND | 71 mo | 117 were free of symptoms 7 pt with symptom recurrence | ND, 13 of failure group had study | ND, 13 of failure group had study | 97% | ND | ND | Age not predictive of failure (14 pt with symptom recurrence, intractable dysphagia, or short-term AE) | B
UK | | 131 | | 7.6% Barrett's | | | | | | | | 127/131
University hospital | | 131
Case-control
O'Boyle 2002 | <40 32% | Nissen | 63% male | 22% no esophagitis | 13/119(11%) abnl | ND | 116/246(47%)hiatal hernia | 5 yr | No difference in post-op heartburn scores by age | ND | ND | ND | ND | No difference in post-op satisfaction scores by age | ND | C
Australia | 40–60 48% | 262/262 | | 66% moderate esophagitis | (>4.4%)
Public hospital | >60 20% | | | 11% severe esophagitis
Case-control | (n=258) | | | (n=218)
Sandbu 2002 | 52 | Low volume Antireflux | 62% male | ND | ND | ND | ND | 4 yr | Age not correlated to symptoms | ND | ND | 89% low vol vs 80% high vol | ND | Age not correlated to patient satisfaction | ND | C
Sweden | 54 | 220/208
Public hospitals-low vs high volume | | High volume Antireflux | 60% male
Amibdirectional cohort | | 225/200
Horvath 1999 | 50 | Toupet | 69% male | ~43% gr III or IV; 28% Stricture; 28% Barrett's (Savary-Miller) | Conducted off meds 5 days prior DeMeester | ND | LES 6.8 mmHg | 22 mo | ND | ND | ND | ND | ND | ND | Age is not predictive of failure (abnl pH) | C
USA | (30–73) | 48/48
Hospital
Case-control
Blom 2002 | 48 med | Nissen | 73% male | 33 (20%) Stricture; 36 (22%) Barrett's | ND | ND | ND | 14 mo | Age not factor for dysphagia after surgery | ND | ND | ND | ND | ND | ND | C
USA | (15–78) | 163/103 | | (Savary-Miller) | Abnl > 14.72) | | | (med)
University hospital | | (preop dysphagia (n=60) excluded from analyses) | | | DeMeester
Case-control
Fernando 2003 | 68 med | Nissen 96% | 28% male | ND | 71 | ND | 13 | 18 mo | No difference between groups for heartburn, dysphagia, cough,regurgitation, chest pain, HRQOL for heartburn | ND | ND | No difference between groups for PPI 17% vs 19% H2RA 9% vs 6% Antacids 14% vs 5% | ND | Time to normal activities similar in both groups; no difference between groups for SF-36 mental & physical | ND | C
USA | (60–80) | Nissen/Collis 4% | | | | | LES mmHg | (med)
University hospital | | 43/35
Retrospective cohort | 41 med | 150/102 | 55% male | | 69 | | 9.5 | 17 mo
| (15–59) | | | | DeMeester | | LES mmHg | (med)
Campos 1999 | <50 yr (n=102) | Nissen | 70% male | 41% erosive esophagitis; | 86% abnl >14.7 | Unknown meds/dose; Rspn to acid suppression therapy: | 75% structurally defective LES; 70% hiatal hernia | 15 mo | 87% excellent/good& 13% poor symptomatic outcomes; age not factor for outcomes | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | >50 yr (n=97) | 233/199 | | 24% Barrett's | DeMeester | 7% complete
University hospital | (15–77) | | | | | 71% partial
Prospective cohort | | | | | | 17% minor
| | | | | | 5% none
Kamolz 2001 | | Nissen 71% | 83(79–95) 68% male | None | 61 | Non-responsive to omeprazole 20–60 mg/day | 2.3 LES mmHg 95% hiatal heenia | 3 yr | All GERD symptoms resolved | ND | ND | 100% | NA | Pt satisfaction 84% excellent, 16% good; 97% would undergo surgery again; GIQLI 120 vs 86 at baseline ↑ | ND | B
Austria | | Toupet 29% | | | Nl < 17.5 DeMeester
Hospital | | 72/72
Prospective cohort
Bammer 2002 | | Nissen (83%) | 83 (79–95) 37% male | 13% stricture, | 64 DeMeester | Non-responsive | 7.7 LES mmHg | 3.1 yr | 96% reported excellent significant improvement for heartburn, dysphagia, cough, regurgitation, chest pain p<0.02 - 0.001 | 3 had endoscopy - 1 Barrett's surveillence, 2 for dysphagia | ND | 19% on PPI or promotility meds | ND | 92% satisfied with surgery decision; Well-being score improved significantly p=0.03 | | C
USA | | Toupet (17%) | | 17% Barrett's
Private hospital | | 30/28
Retrospective cohort

Evidence Table 7b. Age as modifying factor for outcomes after endoscopic therapy

Author,Year | Pre-operative risk assessed | Study and patient characteristics | | | | | Follow up duration | Status at follow up | | | | | | | Quality
Study design | Age Mean(SD) | Intervention | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/Off all anti-secretory meds | Other med use data | QOL/satisfaction | EMS/Others
| | N Enrolled/Follow up
| | Sex
Schumacher 2005 | 48 yr (14) | ERX | Yes | Must have abnormal pH study | Median LES = 10 mm Hg; Excluded hiatal hernia ≥ 3 cm | Yes | 12 mo | Heartburn & regurg scores improved compared to off PPI levels (p<0.0001) & improved after treatment to a level similar to on PPI | No change in 55%; | 28/54 | 65% off PPI at 12 mos; | 86% ≥ 50% PPI ↓ dosage at 12 mos (CI 77–93%) | SF-36-P &-SF-36-M improved compared to off PPI levels (p<0.0001 & p=0.0012), GERD-HRQL improved compared to off PPI levels | Median LES = 9 mm (NS); | B
Prospective Cohort | | 93 | | | | | | | improved in 12%; | (52%) normalized | | | | 6 pts retreated between months 1 & 3.
| | 76 | | | | | | | worsened in 33%
| | 68%M
Triadafilopoulos 2002 & 2001 Included 9 pts from DiBaise, 2002 | 47 yr (12) | STR | Yes | All have abnormal pH study; median DeMeester off meds = 40 | Median LES = 15 mm Hg; | At least partial response to meds | Up to 12 mo | Heartburn score improved compared to baseline off med (p=0.0001) | Esophagitis (grades 1 or 2) present in 31% pre- and 25% post-Rx at 6 mos (NS) | DeMeester = 26.3 (p=0.0001) at 6 mos | At baseline, 88% on PPI, at 12 mos, 30% on PPI (p<0.0001); 40% off all meds | ND | GERD-HRQL improved at 12 mos compared to baseline on meds (p=0.0007); | At 6 mos, median LES=12.6 (p=0.007) | C
Prospective Cohort | | 118 | | | Excluded >2 cm hiatal hernia | | | | | | | | SF-36-P &-M improved (p<0.0001)
| | 94
| | 61%M

Evidence Table 8. Sex as modifying factor for outcomes after laparoscopic fundoplication

Author Yr | Pre-operative risk assessed | Intervention Enrolled/ Final | Baseline patient characteristics | | | | | Follow-up duration | Status at follow up | | | | | | | Quality
Country | Sex | | Age | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | Responded to PPI or H2RA | EMS/Hiatal hernia | | Change in symptoms | Esophagitis status | pH Status | Off PPI/ Off all anti-secretory meds/) | PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ others
Setting
Study design
Stewart 2004 | 61% male | Anterior partial 55% Nissen 27%ONF 17% | 44 | ND | ND | ND | ND | 3.7 | Females had significantly higher level of symptoms: Abdominal pain Diarrhea Indigestion Constipation p=0.043 - 0.001 | ND | ND | Use of PPI, antacids, & H2RA correlate to DeMeester score p<0.001 | ND | 68%–77% reported excellent or good results, 7% reported poor results | Females reported significantly more bloating p=0.001 & inability to vomit p=0.021 | C
UK | | 357 (questionnaire) | | | | | | 2.3
Hospital | | | | | | | | 3.5 Yr (med)
Ambi-directional cohort
Sandbu 2002 | Low vol hospitals | Antireflux | 52 | ND | ND | ND | ND | 4 yr | Sex not correlated to symptoms | ND | ND | 89% low vol vs 80% high vol | ND | Sex not correlated to patient satisfaction | ND | C
Sweden | 62% male | 220/208
Public hospital | High vol hospitals | Antireflux | 54
Ambi-directional cohort | 60% male | 225/200
Jackson 2001 | 54% male | Nissen 95% | 48 (med) | 62% esophagitis | 93% abnl | 21% with partial or no response to PPI | 65% with hiatal hernia | 15 mo | Good response by Visick score 91%, 9% reported poor response, findings confirmed by GERD-HRQL; Sex not predictive of outcomes | ND | ND | ND | ND | ND | ND | C
USA | | Toupet 5% | | 22% Barrett's | DeMeester
University hospital | | 100/81
Prospective cohort
Khajanchee 2004 | 62% male | Nissen | 51 | 62% severe esophagitis | 93% abnl (off meds) | ND | 58% hiatal hernia | 8.8 mo | 89% had reduction or were symptom-free; Sex (?) is risk factor for poor outcomes | ND | 9.7% abnl (133/193 asymptomatic tested) | ND | ND | ND | ND | C
USA | | 223/223 | | | DeMeester (>14.7)
Private center
Case-control
O'Boyle 2002 | 63% male | Nissen | <40 32% | 22% no esophagitis 66% moderate esophagitis 11% severe esophagitis (n=218) | 13/119(11%) abnl | ND | 116/246 (47%) hiatal hernia | 5 yr | Better heartburn scores associated with males p=0.018 | ND | ND | ND | ND | Higher satisfaction score associated with males p=0.015 | ND | C
Australia | | 262/262 | 40–60 48%
Public hospital | | | >60 20% (n=258)
Case-control
Horvath 1999 | 69% male | Toupet | 50 | ~43% gr III or IV; 28% Stricture; 28% Barrett's (Savary-Miller) | Conducted off meds 5 days prior DeMeester | ND | LES 6.8 mmHg | 22 mo | ND | ND | Sex not factor for abnormal DeMeester score | ND | ND | ND | ND | C
USA | | 48/48
Hospital
Case-control
Blom 2002 | 27% female | Nissen | 48 med (15–78) | 33 (20%) Stricture; 36 (22%) Barrett's (Savary-Miller) | ND | ND | ND | 14 mo (med) | Female sex not factor for postop dysphagia | ND | ND | ND | ND | ND | ND | C
USA | | 163/103 (preop dysphagia (n=60) excluded from analyses) | | | Abnl > 14.72)
University hospital | | | | | DeMeester
Case-control
Campos 1999 | 70% male | Nissen | 49 med (15–77) | 41% erosive esophagitis; 24% Barrett's | 86% (abnl >14.7, off meds) | Unknown meds/dose; response to acid suppression therapy: | 75% structurally defective LES; 70% hiatal hernia | 15 mo | 87% excellent/good & 13% poor symptomatic outcomes; sex not factor for outcomes | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | | 199/199 | | | DeMeester | 7% complete
University hospital | | | | | | 71% partial
Prospective cohort | | | | | | 17% minor
| | | | | | 5% none

Evidence Table 9. Preoperative esophagitis as a modifying factor for surgical, or endoscopic treatment outcome

Author, Year | Preop Factor(s) Assessed | Intervention Enrolled/ Final | Patient characteristics | | | | Follow up duration | Status at follow up | | | | | | | Quality
Study design | | | Excluded ≥ grade 3 esophagitis ; % ≥grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ Others
Desai, 2003 | Esophagitis | LNF or LPA | 58% ≥grade 3 | mean DeMeester score was abnormal (unknown if on/off meds) | ND | ND | range: 6–109 mo | Dysphagia: | ND | ND | No difference in rates of patients off all meds | ND | No difference in % satisfied | No difference in rates of reoperation | C
case control | | 597 | | | | | | [underlined: Factor: 25%] | | | No difference in rates of patients off PPIs
| | 414 | | | | | | [underlined: No Factor] ^ 3 ^: 14%
| | | | | | | | p<.05
| | | | | | | | No difference in overall symptomatic improvement
| | | | | | | | No difference in rates of any symptom assessed^2^
O'Boyle, 2002 | Esophagitis | ONF | ~77% ≥grade 3 | 11% had abnormal % time at low pH (unknown if on/off meds) | 47% had hiatal hernia | ND | 5 yr | No difference in heartburn or dysphagia scores | ND | ND | ND | ND | No difference in satisfaction score | ND | C
case control | | 262
| | 262
Campos, 1999 | Esophagitis | LNF | ND | 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Power 2004 | Esophagitis | LNF | 11% ≥ grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER symptoms or dysphagia^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Blom, 2002 | Esophagitis | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103
Jackson, 2001 | Esophagitis | LNF or LPA | ≥22% ≥grade 3 | 93% had abnormal DeMeester score (unknown if on/off meds) | 74% had structurally defective LES, 65% had hiatal hernia | 79% | average: 15 mo | No difference in Visick grade^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 100
| | 81
Triadafilopoulos, 2002 | Esophagitis | STR | Excluded ≥grade 3 | 100% had abnormal pH study; median DeMeester = 40 (off meds) | Median LES =15 mm Hg; Excluded >2 cm hiatal hernia | 100% had at least partial response to meds | Up to 12 mo | No difference in heartburn score | ND | No difference in % time at low pH | No difference in rates of patients off PPIs or off all meds | ND | ND | ND | C
Prospective Cohort | | 118
| | 94
Schumacher, 2005 | Esophagitis | ERX | Excluded ≥grade 3 | 100% had abnormal pH study (off meds) | Median LES = 10 mm Hg; Excluded hiatal hernia ≥ 3 cm | 100% | 12 mo | No difference in heartburn or regurgitation scores | No difference in changes in esophagitis severity | No difference in pH status | No difference in rates of patients off PPIs | No difference in rates of ↓PPI dose | No difference in SF-36 or GERD-HRQL scores | No difference in LES pressures | B
Prospective Cohort | | 93
| | 76
Cohen, 2005 | Esophagitis | ERX | Included 1 pt with ≥ grade 3 | 100% had abnormal pH study (unknown if on/off meds) | Included 12 pts with hiatal hernia ≥ 3 cm | 100% | Up to 24 mo | | | | | No difference in rates of ↓PPI dose^1,^ ^4^ | | | C
Prospective Cohort | | 144
| | 64
Khajanchee, 2004 | Esophagitis grade | ONF | ND | 93% had abnormal DeMeester score (off meds) | 58% had hiatal hernia | ND | median: 8.8 mo | No difference in rates of heartburn/ regurgitation ≥1x/wk^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 223
| | 223
Deviere, 2005 | Esophagitis grade | ERX | Excluded ≥grade 3 | 100% had pH study (off PPI) | Excluded hiatal hernia ≥ 5 cm | 100% | 3 mos | ND | ND | ND | ND | No difference in rates of PPI reduction≥ 50% pre-endo dose | ND | ND | B
RCT | | 32
| | 31
Bell, 1999 | Grade 2–4 esophagitis | LPA | ≥ 36% ≥grade 3 | mean DeMeester score abnormal (off meds) | ND | ND | mean: 30 mo | No difference in rates of dysphagia^1^ | ND | ND | ND | ND | ND | ND | C
case control | | 143
| | 138
Horvath, 1999 | Grade 3–4 Esophagitis | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | Abnormal DeMeester score: | ND | ND | ND | ND | C
case control | | 48 | | | | | | | | [underlined: Factor: 16/21 (76%)]
| | 39 | | | | | | | | [underlined: No Factor] ^ 3 ^: 6/27 (22%)
| | | | | | | | | | p<.05 ^ 1 ^
Blom, 2002 | Stricture | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103
Horvath, 1999 | Stricture | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | No difference in rates of abnormal DeMeester score^1^ | ND | ND | ND | ND | C
case control | | 48
| | 39
Campos, 1999 | Carditis | LNF | ND | 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Campos, 1999 | Intestinal metaplasia in cardiac-type epithelium | LNF | ND | 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Campos, 1999 | Barrett's esophagus | LNF | ND | 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Power 2004 | Barrett's esophagus | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER Sx/ dysphagia^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Blom, 2002 | Barrett's esophagus | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103
Jackson, 2001 | Barrett's esophagus | LNF or LPA | ≥22% ≥grade 3 | 93% had abnormal DeMeester score (unknown if on/off meds) | 74% had structurally defective LES, 65% had hiatal hernia | 79% | average: 15 mo | No difference in Visick grade^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 100
| | 81
Horvath, 1999 | Barrett's esophagus | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | No difference in rates of abnormal JD score^1^ | ND | ND | ND | ND | C
case control | | 48
| | 48
Blom, 2002 | Length of Barrett's esophagus (continuous) | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103

1 Significance adjusted for covariates

2 Symptoms assessed were: heartburn, regurgitation, water brash, nocturnal aspiration, chest pain, bloating and ability to belch

3 Factor and No Factor: patients with and without the preoperative modifying factor assessed in the study

4 Outcome for multivariate analysis not explicitly stated, but assumed to be the primary outcome of the study, >50% reduction in PPI use from baseline

Evidence Table 10. Preoperative esophageal pH status as a modifying factor for medical, surgical, or endoscopic treatment outcome

Author,Yr | Preop Factor(s) Assessed^2^ | Intervention | Patient characteristics | | | | Follow up duration | Status at follow up | | | | | | | Quality
Study design | | Enrolled/ Final | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/satisfaction | EMS/Others
O'Boyle, 2002 | Abnormal % time at low pH^3^ | ONF | ~77% ≥grade 3 | 11% had abnormal % time at low pH (unknown if on/off meds) | 47% had hiatal hernia | ND | 5 yr | Heartburn score: | ND | ND | ND | ND | Satisfaction score: | ND | C
case control | | 262 | | | | | | [underlined: Factor:] 2 | | | | | [underlined: Factor:] 8
| | 262 | | | | | | [underlined: No factor] ^4^: 3 | | | | | [underlined: No factor] ^4^: 5
| | | | | | | | p<.01 | | | | | P<.001
| | | | | | | | Dysphagia score:
| | | | | | | | [underlined: Factor:] 2
| | | | | | | | [underlined: No factor] ^4^: 5
| | | | | | | | p=.002
Campos, 1999 | % time at low pH^3^ (continuous) | LNF | ND | 78% had abnormal % time at low pH (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates patients were off all meds^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Anvari, 2003 | % time at low pH^3^ (continuous) | LNF | ND | Mean % time at low pH: 8% (off meds) | Mean LES pressure: 7.2 mmHg | 36% | 5 yr | No difference in GERD symptom score | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 332 | | | | | | P=.67^1^
| | 181
Power, 2004 | % time at low pH^3^ (continuous) | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER symptoms/ dysphagia^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Triadafilopoulos, 2002 | % time at low pH^3^ (continuous) | STR | Excluded ≥grade 3 | 100% had abnormal pH study; median DeMeester = 40 (off meds) | Median LES =15 mm Hg; Excluded >2 cm hiatal hernia | 100% had at least partial response to meds | Up to 12 mo | No difference in heartburn score | ND | No difference in % time at low pH^3^ | No difference in rates of patients off PPIs or off all meds | ND | ND | ND | C
Prospective Cohort | | 118
| | 94
Topart, 1999 | % time at low pH^3^ (continuous) | LNF, LPA, ONF or OPA | 26% ≥grade 3 | mean % time at low pH: 20.6% (unknown if on/off meds) | mean LES pressure: 9.5 mmHg, 76% had hiatal hernia | ND | Mean: 30.6 mo | ND | ND | ND | ND | ND | ND | No difference in symptoms with esophagitis and/or hiatal hernia | B
case control | | 88
| | 88
Costantini, 1996 | % time at low pH^3^ (continuous) | H2RA or OME | ≤24% ≥grade 3 | 100% had abnormal DeMeester score (off meds) | 34% had defective LES | Not applicable | median: 31 mo | ND | ND | ND | No difference in rates of patients off all meds | ND | ND | ND | B
non-randomized controlled trial | | 55
| | 55
Deviere, 2005 | % time at low pH^3^ (continuous) | ERX | Excluded ≥grade 3 | 100% had pH study (off PPI) | Excluded hiatal hernia ≥ 5 cm | 100% | 3 mos | ND | ND | ND | ND | No difference in rates of PPI reduction≥ 50% pre-endo dose | ND | ND | B
RCT | | 32
| | 31
Power, 2004 | % supine time at low pH^3^ (continuous) | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER symptoms/ dysphagia^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Costantini, 1996 | % supine time at low pH^3^ (continuous) | H2RA or OME | ≤24% ≥grade 3 | 100% had abnormal DeMeester score (off meds) | 34% had defective LES | Not applicable | median: 31 mo | ND | ND | ND | No difference in rates of patients off all meds | ND | ND | ND | B
non-randomized controlled trial | | 55
| | 55
Power, 2004 | % upright time at low pH^3^ (continuous) | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | ↑Factor ^ 4 ^ associated with ↑GER symptoms/ dysphagia ^ 1 ^ | ND | ND | ND | ND | ND | ND | B
case control | | 131 | | | | | | p=.04
| | 131
Costantini, 1996 | % upright time at low pH^3^ (continuous) | H2RA or OME | ≤24% ≥grade 3 | 100% had abnormal DeMeester score (off meds) | 34% had defective LES | Not applicable | median: 31 mo | ND | ND | ND | No difference in rates of patients off all meds | ND | ND | ND | B
non-randomized controlled trial | | 55
| | 55
Khajanchee, 2004 | Abnormal DeMeester score (>14.7) | ONF | ND | 93% had abnormal DeMeester score (off meds) | 58% had hiatal hernia | ND | median: 8.8 mo | Heartburn/ regurgitation ≥1x/wk: | ND | ND | ND | ND | ND | ND | B
case control | | 223 | | | | | | [underlined: Factor:17/208 (8%)]
| | 223 | | | | | | [underlined: No factor] ^ 4 ^: 6/15 (40%)
| | | | | | | | p<.05 ^ 1 ^
Campos, 1999 | DeMeester score (continuous) | LNF | ND | 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | Off all meds: | ND | ND | ND | B
prospective cohort | | 233 | | | | | | | | | Factor:154/170 (91%)
| | 199 | | | | | | | | | No factor ^ 4 ^: 19/29 (66%)
| | | | | | | | | | | p<.001 ^ 1 ^
Power, 2004 | DeMeester score (continuous) | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER symptoms/ dysphagia^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Blom, 2002 | DeMeester score (continuous) | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103
Jackson, 2001 | DeMeester score (continuous) | LNF or LPA | ≥22% ≥grade 3 | 93% had abnormal DeMeester score (unknown if on/off meds) | 74% had structurally defective LES, 65% had hiatal hernia | 79% | avg: 15 mo | No difference in Visick grade^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 100
| | 81
Horvath, 1999 | DeMeester score (continuous) | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5 mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | ↑Factor^4^ associated with ↑DeMeester score p<.05^1^ | ND | ND | ND | ND | B
case control | | 48
| | 39
Cohen, 2005 | “esophageal acid exposure” | ERX | Included 1 pt with ≥ grade 3 | 100% had abnormal pH study (unknown if on/off meds) | Included 12 pts with hiatal hernia ≥ 3 cm | 100% | Up to 24 mo | | | | | No difference in rates of ↓PPI dose^5^ | | | C
Prospective Cohort | | 144
| | 64

1 Significance adjusted for covariates

2 Unless otherwise indicated, all pH studies were performed for 24 hours.

3 Low pH is defined as < 4 by virtually all studies. An abnormal percentage of time spent at low pH is defined as 4.4% by virtually all studies

4 Factor and No Factor: patients with and without the preoperative modifying factor assessed in the study

5 Outcome for multivariate analysis not explicitly stated, but assumed to be the primary outcome of the study, >50% reducdtion in PPI use from baseline

Evidence Table 11. Preoperative esophageal manometric status as a modifying factor for medical, surgical or endoscopic treatment outcome

Author, Yr | Preop Factor(s) Assessed | Intervention | Patient characteristics | | | | Follow up duration | Status at follow up | | | | | | | Quality
Study design | | Enrolled/ Final | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ Others
LOWER ESOPHAGEAL SPHINCTER (LES) INCOMPETENCE ^ 2 ^
Campos, 1999 | Incompetent LES | LNF | ND | 78% had abnormal % time at low pH, 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds ^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Bell, 1999 | Incompetent LES | LPA | ≥ 36% ≥grade 3 | mean DeMeester score abnormal (off meds) | ND | ND | mean: 30 mo | No difference in rates of dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 143
| | 138
Ritter, 1998 | Incompetent LES | LNF | ND | 100% with abnormal % time at low pH (unknown if on/off meds) | 68% had structurally defective LES | ND | median: 18 mo | No difference in severity of GER Symptoms/ dysphagia | ND | ND | ND | ND | ND | ND | C
prospective cohort | | 123
| | 103
ESOPHAGEAL SEGMENTS LENGTH
Yau, 2000 | Esophageal length (continuous) | LAS | 26% ≥grade 3 | ND | 52% had hiatal hernia | ND | median: 2 yr | ND | ND | ND | ND | ND | ND | No difference in overall rates of reoperation | B
prospective cohort | | 774
| | 484
Blom, 2002 | Esophageal length: monometric, total and abdominal (all continuous) | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia for any of the factor factors | ND | ND | ND | ND | ND | ND | C
case control | | 163
| | 103
Khajanchee, 2004 | total LES length | ONF | ND | 93% had abnormal DeMeester score (off meds) | 58% had hiatal hernia | ND | median: 8.8 mo | No difference in rates of heartburn/ regurgitation ≥1x/wk ^1^ | ND | ND | ND | ND | ND | ND | B
case control | (continuous) | 223
| | 223
LOWER ESOPHAGEAL SPHINCTER (LES) PRESSURE
Horvath, 1999 | low LES pressure (<5 mmHg) | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5 mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | abnormal DeMeester score: | ND | ND | ND | ND | B
case control | | 48 | | | | | | | | [underlined: Factor:] ~16/24 (67%)
| | 39 | | | | | | | | [underlined: No factor] ^7^ : ~8/24 (33%)
| | | | | | | | | | p<.05 ^1^
Costantini, 1996 | defective LES ^3^ | H2RA or OME | ≤24% ≥grade 3 | 100% had abnormal DeMeester score (off meds) | 34% had defective LES ^3^ | Not applicable | median: 31 mo | ND | ND | ND | Off all meds: | ND | ND | ND | B
non-randomized controlled trial | | 55 | | | | | | | | | [underlined: Factor:] 1/14 (7%)
| | 55 | | | | | | | | | [underlined: No factor] ^7^ : 13/27 (48%)
| | | | | | | | | | | p<.05
Patti, 2003 | LES pressure | LNF or LPA | 30% ≥grade 3 | mean reflux score was abnormal (off meds) | 61% had hiatal hernia | ND | avg: 17 mos | NS difference in heartburn, regurgitation or dysphagia | | | | | | | C
retrospective cohort | | 520
| | 280
Khajanchee, 2004 | LES pressure (continuous) | ONF | ND | 93% had abnormal DeMeester score (off meds) | 58% had hiatal hernia | ND | median: 8.8 mo | No difference in rates of heartburn/ regurgitation ≥1x/wk ^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 223
| | 223
Anvari, 2003 | LES pressure (continuous) | LNF | ND | mean % time at low pH: 8.4 (off meds) | Mean LES pressure: 7.2 mmHg | 36% | 5 yr | No difference in GERD symptom score ^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 332
| | 181
Power, 2004 | LES pressure (continuous) | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | No difference in rates of GER symptoms/ dysphagia ^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Blom, 2002 | LES pressure (continuous) | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | ↑Factor ^7^ associated with ↑dysphagia | ND | ND | ND | ND | ND | ND | C
case control | | 163 | | | | | | p=.004
| | 103
Triadafilopoulos, 2002 | LES pressure (continuous) | STR | Excluded ≥grade 3 | 100% had abnormal pH study; median DeMeester = 40 (off meds) | Median LES =15 mm Hg; Excluded >2 cm hiatal hernia | 100% had at least partial response to meds | Up to 12 mo | No difference in heartburn score | ND | No difference in % time at low pH | No difference in rates of patients off PPIs or off all meds | ND | ND | ND | C
Prospective Cohort | | 118
| | 94
Topart, 1999 | LES pressure (continuous) | ARS | 26% ≥grade 3 | mean % time at low pH: 20.6% (unknown if on/off meds) | mean LES pressure: 9.5 mmHg, 76% had hiatal hernia | ND | mean: 30.6 mo | ND | ND | ND | ND | ND | ND | No difference in symptoms with esophagitis and/or hiatal hernia | B
case control | | 88
| | 88
DISORDERED ESOPHAGEAL MOTILITY
Booth, 2002 | Esophageal hypomotility (Castell criteria) | LNF | ND | 100% had abnormal % time at low pH (off meds) | 43% had hiatal hernia | ND | 1 yr | No difference in dysphagia scores | ND | No difference in % time at low pH | ND | ND | ND | No difference in LES pressure | A
prospective cohort | | 117 | | | | | | No difference in DeMeester Symptom Scores | | | | | | Dilation/ Re-operation:
| | 117 | | | | | | | | | | | | [underlined: Factor:] 0/35 (0%)
| | | | | | | | | | | | | | [underlined: No factor] ^7^ : 10/82 (12%)
| | | | | | | | | | | | | | p=.03
Triadafilopoulos, 2002 | Amplitude of contractions (continuous) | STR | Excluded ≥grade 3 | 100% had abnormal pH study; median DeMeester = 40 (off meds) | Median LES =15 mm Hg; Excluded >2 cm hiatal hernia | 100% had at least partial response to meds | Up to 12 mo | No difference in heartburn score | ND | No difference in % time at low pH | No difference in rates of patients off PPIs or off all meds | ND | ND | ND | C
Prospective Cohort | | 118
| | 94
Costantini, 1996 | Amplitude of contractions (continuous) | H2RA or OME | ≤24% ≥grade 3 | 100% had abnormal DeMeester score (off meds) | 34% had defective LES ^3^ | Not applicable | median: 31 mo | ND | ND | ND | No difference in rates of patients off all meds | ND | ND | ND | B
non-randomized controlled trial | | 55
| | 55
Horvath, 1999 | Esophageal hypomotility, dysmotility, low distal wave amplitude (<30 mmHg) ^4^ | LPA | ≥~40% ≥grade 3 | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5 mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | No difference in rates of abnormal DeMeester score for any of the factor factors ^1^ | ND | ND | ND | ND | B
case control | | 48
| | 39
Jackson, 2001 | low distal wave amplitude (<30 mmHg) | LAS | ≥22% ≥grade 3 | 93% had abnormal DeMeester score (unknown if on/off meds) | 74% had incompetent LES, 65% had hiatal hernia | 79% | mean: 15 mo | No difference in Visick grade ^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 100
| | 81
Winslow, 2003 | High distal wave amplitude (>71 mmHg) | LAS | ≥ 23% ≥grade 3 | mean DeMeester score was abnormal (unknown if on/off meds) | 59% had hiatal hernia | ND | mean: 18.4 mo | No difference in rates of heartburn/ regurgitation | ND | ND | ND | ND | ND | ND | C
prospective cohort | | 168
| | 124
Winslow, 2003 | Nonspecific spastic disorder ^5^ | LAS | ≥ 23% ≥grade 3 | mean DeMeester score was abnormal (unknown if on/off meds) | 59% had hiatal hernia | ND | mean: 18.4 mo | Heartburn/ regurgitation: | ND | ND | Off all meds: | ND | No difference in change in overall health | ND | C
prospective cohort | | 168 | | | | | | [underlined: Factor:] 25% | | | [underlined: Factor:] 81%
| | 124 | | | | | | [underlined: No factor] ^7^ : 7% | | | [underlined: No factor] ^7^ : 95%
| | | | | | | | p=.012 | | | p=.014
MISCELLANEOUS
Blom, 2002 | Competent LES | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | Dysphagia: | ND | ND | ND | ND | ND | ND | C
case control | | 163 | | | | | | [underlined: Factor:] 3/80 (4%)
| | 103 | | | | | | [underlined: No factor] ^7^ : 5/23 (22%)
| | | | | | | | p=.01
Klaus, | Defective LES and impaired peristalsis ^6^ | OME | excluded ≥grade 3 | median DeMeester score was abnormal (off meds) | 80% had defective LES | No history of med use | 1 yr | ND | ND | ND | ND | ND | Symptoms +/- esophagitis: | ND | C
2003 | | | | | | | | | | | | | [underlined: Normal LES/ peristalsis:] 8%
open, single-arm trial | | | | | | | | | | | | | [underlined: Defective LES + Normal peristalsis:] 38%
| | | | | | | | | | | | | [underlined: Defective LES/ peristalsis:] 80%
| | | | | | | | | | | | | p<.05

1 Significance adjusted for covariates

2 Incompetent LES is defined by: LES length< 2cm, intra-abdominal length< 1cm and/or LES resting pressure criteria. In studies by Campos, 1999 and Ritter, 1998 the LES pressure criteria is < 6mmHg. In the study by Bell, 1999 the criteria is <10 mmHg

3 Defective LES was defined as an LES vector volume (calculated by Bombeck criteria) <5% below normal controls

4 Esophageal hypomotility was defined as contraction amplitudes<30 mmHg at 2 or more levels. Dysmotility was defined as the presence of >60% tertiary or simultaneous contractions or >60% dropped peristalses.

5 Nonspecific spastic disorder is defined as any one or a combination of the following: high distal wave amplitude, prolonged distal wave duration, excessive double peaked waves or any triple peaked waves

6 Defective LES was defined as resting pressure <9 mmHg. Impaired peristalsis was defined as defective contraction waves≤ 20%

7 Factor and No Factor: patients with and without the preoperative modifying factor assessed in the study

Evidence Table 12. Preoperative presence of hiatal hernia as a modifying factor for surgical or endoscopic treatment outcome62

Author, Yr | Preop Factor(s) Assessed | Intervention | Patient characteristics | | | | Follow up duration | Status at follow up | | | | | | | Quality
Study design | | Enrolled/ Final | Excluded ≥ grade 3 esophagitis ; % ≥grade 3 | pH status | EMS/hiatal hernia | Responded to PPI or H2RA | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ Others
O'Boyle, 2002 | hiatal hernia | ONF | ~77% ≥grade 3 | 11% had abnormal % time at low pH (unknown if on/off meds) | 47% had hiatal hernia | ND | 5 yr | No difference in heartburn or dysphagia scores ^1^ | ND | ND | ND | ND | No difference in satisfaction score ^1^ | ND | C
case control | | 262
| | 262
Khajanchee, 2004 | hiatal hernia, excluded para-esophageal (type 2 or 3) hernias | ONF | ND | 93% had abnormal DeMeester score (off meds) | 58% had hiatal hernia | ND | median: 8.8 mo | No difference in symptom score ^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 223
| | 223
Campos, 1999 | hiatal hernia >2cm, excluded para-esophageal hernias | LNF | ND | 78% had abnormal % time at low pH, 85% had abnormal DeMeester score (off meds) | 75% had incompetent LES, 70% had hiatal hernia | 78% | median: 15 mo | ND | ND | ND | No difference in rates of patients off all meds ^1^ | ND | ND | ND | B
prospective cohort | | 233
| | 199
Power, 2004 | hiatal hernia> 3cm | LNF | 11% ≥grade 3 | mean % time at low pH: 25% (unknown if on/off meds) | ND | ND | mean: 70.6 mo | Factor ^3^ associated with ↑GERD symptoms/ dysphagia P=.003 ^1^ | ND | ND | ND | ND | ND | ND | B
case control | | 131
| | 131
Blom, 2002 | hiatal hernia >2 cm | LNF | ND | 100% had abnormal DeMeester score (unknown if on/off meds) | ND | ND | median: 14 mo | No difference in rates of dysphagia by presence or size of hernia | ND | ND | ND | ND | ND | ND | B
case control | | 163
| | 103
Jackson, 2001 | hiatal hernia | LNF or LPA | ≥22% | 93% had abnormal DeMeester score (unknown if on/off meds) | 74% had structurally defective LES, 65% had hiatal hernia | 79% | avg: 15 mo | No difference in Visick grade ^1^ | ND | ND | ND | ND | ND | ND | B
prospective cohort | | 100 | ≥grade 3
| | 81
Cohen, 2005 | hiatal hernia | ERX | Included 1 pt with ≥ grade 3 | 100% had abnormal pH study (unknown if on/off meds) | Included 12 pts with hiatal hernia ≥ 3 cm | 100% | up to 24 mo | ND | ND | ND | ND | No difference in rates of ↓PPI dose^1.2^ | ND | ND | C
Prospective Cohort | | 144
| | 64
Horvath, 1999 | hiatal hernia, excluded para-esophageal hernias | LPA | ≥~40% | mean DeMeester score was abnormal (off meds) | ~48% had low LES pressure (<5 mmHg), 63% had hiatal hernia | ND | mean: 22 mo | ND | ND | No difference in rates of abnormal DeMeester score | ND | ND | ND | ND | B
case control | | 48 | ≥grade 3
| | 48
Deviere, 2005 | hiatal hernia <5cm | ERX | Excluded | 100% had pH study (off PPI) | Excluded hiatal hernia ≥ 5 cm | 100% | 3 mo | ND | ND | ND | ND | No difference in rates of PPI reduction≥ 50% pre-endo dose | ND | ND | B
RCT | | 32 | ≥grade 3
| | 31

^1^ Significance adjusted for covariates

^2^ Outcome for multivariate analysis not explicitly stated, but assumed to be the primary outcome of the study, >50% reduction in PPI use from baseline

Evidence Table 13. Patient response to anti-secretory medications as modifying factor for outcomes after laparoscopic fundoplication

Author Yr | Pre-operative variable assessed | Intervention | Baseline patient characteristics | | | | Follow-up duratioin | Status at follow up | | | | | | | Quality
| Responded to PPI or H2RA | Enrolled/ Final | Age | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | EMS/ Hiatal hernia | | Change in symptoms | Esophagitis status | pH normalized | Off PPI/ Off all anti-secretory meds | PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ others
Country | | | Sex
Setting
Study design
Power 2004 | ND | Nissen | 43 | 48% esophagitis | 40 | Unknown # of hiatal hernia > 3 cm | 71 mo | 117 were free of symptoms, 7 pt with symptom recurrence | ND, 13/14 in failed group had study | ND, 13/14 in failed group had study | 97% | ND | ND | Non-response to preop PPI were predictive of surgical failure p<0.001 | B
UK | | 131/131 | 47% male | 7.6% 's | DeMeester | | | | | | 127/131
University hospital | | | | | PH study not required if severe esophagitis & rspn to PPI
Case-control
Anvari 2003 | All on PPI; 120 (36%) had adequate control to PPI up to 120 mg/day | Nissen | 47 | ND | ND; obtained off meds 5 day prior; reflux criteria pH<4 | 7.2 LES mmHg hiatal hernia: 36(11%) > 3 cm 16(4.8%) >7 cm 8 pts with >50% stomach herniated through hiatus | 5 yr | Improved symptom score - scores obtained off meds; responders to PPI tx correlated to symptomatic response to surgery p=0.004 | ND | 9 (5%) had abnl pH | 21 (12%) back on anti-secretory meds for heartburn or dyspepsia | ND | 86% satisfied, but 89% would undergo surgery again; no difference in satisfaction between responders & non-responders | Hernia reduced successfully for all cases | C
Canada Hospital | | 332/181 | 38% male
Cohort
Jackson 2001 | 79% complete response, 21% with partial or no response to PPI | Nissen 95% | 48 (med) | 62% esophagitis | 93% abnl | 65% with hiatal hernia | 15 mo | Good response by Visick score 91%, 9% reported poor response | ND | ND | ND | ND | 12 days - return to work, 37 days - full physical activity; GERD-HRQL scores highly associated with Visick grade p<0.00001 | Complete response to acid suppression tx associated with good outcomes (Visick score) p<0.0007 | C
USA | | Toupet 5% | 54% male | 22% Barrett's | DeMeester
University hospital | | 100/81
Prospective cohort
Campos 1999 | Response to acid suppression therapy: | Nissen | 49 med (15-77) | 41% erosive esophagitis; 24% Barrett's | 86% (abnl >14.7, off meds) | 75% structurally defective LES; 70% hiatal hernia | 15 mo | 87% excellent/good& 13% poor symptomatic outcomes; response vs no response to therapy is factor for successful outcomes, 92% vs 68% p=0.00008 | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | 7% complete | 199/199 | 70% male | | DeMeester
University hospital | 71% partial
Prospective cohort | 17% minor
| 5% none
| Unknown meds/dose

Evidence Table 14. Patient symptoms as modifying factor for outcomes after laparoscopic fundoplication

Author Yr | Pre-operative risk assessed | Intervention | Baseline patient characteristics | | | | | Follow-up duration | Status at follow up | | | | | | | Quality
Country | Symptoms | Enrolled/Final | Age | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | Responded to PPI or H2RA | EMS/Hiatal hernia | | Change in symptoms | Esophagitis status | pH status | Off PPI/Off all anti-secretory meds | PPI dose or now responds to dose that failed before Rx | QOL/satisfaction | EMS/others
Setting | | | Sex
Study design
Ritter 1998 | 85% typical symptoms (heartburn, regurgitation, dysphagia); 15% atypical (cough, asthma, chest pain, & other complaint) | Nissen | 49 | ND | ND | ND | 68% structurally defective LES | 18 mo(med) | Symptomatic outcomes rated excellent /good in 90%, fair/poor in 10%; pts w/typical vs atypical symptoms had significantly better symptomatic outcomes | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | | 123/103 | 74% male
University hospital
Prospective cohort
Power 2004 | Graph data: | Nissen | 43 | 48% esophagitis, 7.6% Barrett's | 40 DeMeester | ND | Unknown # of hiatal hernia > 3 cm | 71 mo | 117 were free of symptoms; 7 pt with symptom recurrence | ND, 13/14 in failed group had study | ND, 13/14 in failed group had study | 97% 127/131 | ND | ND | Preopsymptoms of heartburn or dysphagia not predictive of treatment failure | B
UK | ~88% heartburn | 131/131 | 47% male | | PH study not required if severe esophagitis & rspn to PPI
University hospital | ~30% regurgitation
Case-control | ~40% foregut flatulence
| ~25% vomiting
| ~15% dysphagia
| ~7% respiratory compromise
Anvari 2003 | Graph data: | Nissen | 47 | ND | Study conducted off meds 5 day prior; reflux criteria pH<4 | All on PPI; 120 (36%) had adequate control to PPI up to 120 mg/day | 7.2 LES mmHg Hiatal hernia: 36(11%) > 3 cm 16(4.8%) >7 cm 8 pts with >50% stomach herniated through hiatus | 5 yrs | 21 had recurrence of heartburn or dyspepsia; Severe preop GERD symptom score correlated well to symptomatic response to surgery p<0.001 | ND | 9 (5%) had abnl pH | 21 (12%) back on anti-secretory meds for heartburn or dyspepsia | ND | 86% satisfied, but 89% would undergo surgery again | Hernia reduced for all pts | C
Canada | ~40 symptom score for heartburn, regurgitation, bloating, dysphagia, epigastric or retrosternal pain, cough | 332 | 38% male
Hospital | Scores obtained on & off meds | 181
Cohort
Jackson 2001 | 76 (94%) typical symptoms (heartburn, regurgitation); 63 (78%) atypical symptoms (hoarseness, cough, respiratory complaints) | Nissen 95% | 48 (med) | 62% esophagitis | 93% abnl | 21% with partial or no response to PPI | 65% with hiatal hernia | 15 mo | Good response by Visick score 91%, 9% reported poor response; typical symptoms associated with good outcomes p<0.002 | ND | ND | ND | ND | 12 days to work, 37 days to full physical activity; GERD-HRQL scores highly associated with Visick grade p<0.00001 | ND | C
| | Toupet 5% | 54% male | 22% Barrett's | DeMeester
USA | | 100/81
University hospital
Prospective cohort
Bell 1999 | Visick symptom scale | Toupet | ND | ND | Study conducted off meds (n=80) DeMeester | 36 PPI > 8 wk, 22 unkn meds or duration, 14 no meds | ND | ND | 21 failures (15%): 19 with recurrent symptoms, 2 had dysphagia | ND | ND | ND | 1 pt responding with PPI | ND | Heartburn, reflux, dysphagia not predictor for success/failure | C
USA | | 143/138 | ND | | | | | “pts seen up to 3 mo & every 6 mo”
Hospital
Case-control
Horvath 1999 | Heartburn | Toupet | 50 | ~43% gr III or IV; | Conducted off meds 5 days prior DeMeester | ND | LES 6.8 mmHg | 22 mo | ND | ND | ND | ND | ND | ND | Preop symptoms & symptom yrs not predictors for failure (abnl pH) | C
USA | Dysphagia | 48/48 | 69% male | 28% Stricture; 28% Barrett's
Hospital | Pulmonary | | | (Savary-Miller)
Case-control | Water-brash
| Odynophagia
| Nausea/mesis
Blom 2002 | ND | Nissen | 48 med (15-78) | 33 (20%) Stricture; 36 (22%) Barrett's | ND | ND | ND | 14 mo | Symptoms not factor for postop dysphagia | ND | ND | ND | ND | ND | ND | C
USA | | 163/103 | 73% male | (Savary-Miller) | (abnl > 14.72) | | | (med)
University hospital | | (preop dysphagia (n=60) excluded from analyses) | | | DeMeester
Case-control
Campos 1999 | 80% Typical (heartburn, regurgitation, dysphagia) | Nissen | 49 med (15-77) | 41% erosive esophagitis; 24% Barrett's | 86% (abnl >14.7, off meds) | Unknown meds/dose; response to acid suppression therapy: | 75% structurally defective LES; 70% hiatal hernia | 15 mo | 87% excellent/good& 13% poor symptomatic outcomes; typical vs atypical symptoms factor for successful outcomes, 92% vs 68% p=0.0001 | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | 20% Atypical (hoarseness, cough, wheeze, chest pain) | 199/199 | 70% male | | DeMeester | 7% complete
University hospital | | | | | | 71% partial
Prospective cohort | | | | | | 17% minor
| | | | | | 5% none

Evidence Table 15. Weight as modifying factor for outcomes after ARS

Author Yr | Pre-Op Risk(s) Assessed (R) | Intervention | Baseline patient characteristics | | | | | Follow-up duration | Status at follow up | | | | | | | Quality
Country | Weight | Enrolled/Final | Age | Excluded ≥ grade 3 esophagitis; % ≥ grade 3 | pH status | Responded to PPI or H2RA | EMS/Hiatal hernia | | Change in symptoms | Esophagitis status | pH status | Off PPI/Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/satisfaction | EMS/others
Setting | | | Sex
Study design
Sandbu ^1^ 2002 | Low volume hospital | ARS | 52 | ND | ND | ND | ND | 4 yr | ND | ND | ND | 89% low vol vs 80% high vol | ND | Increasing BMI correlated to patient satisfaction P=0.0006 | ND | C
Sweden | BMI 26.4 | 220/208 | 62% male
Public hospital | High volume hospital | ARS | 54
Ambi-directional cohort | BMI 26.3 | 225/200 | 60% male
O'Boyle 2002 | <70Kg 50 (22%) | Nissen | <40 32% | 22% no esophagitis | 13/119 (11%) abnl (>4.4%) | ND | 116/246 (47%) hiatal hernia | 5 yr | No difference in post-op heartburn scores by weight | ND | ND | ND | ND | No difference in post-op satisfaction scores by weight | ND | C
Australia | 70-90Kg 123 (54%) | 262/262 | 40-60 48% | 66% moderate esophagitis
Public hospital | >90Kg 54 (24%) | | >60 20% | 11% severe esophagitis
Case-control | (n=227) | | (n=258) | (n=218)
| | | 63% male
Bell 1999 | ND | Toupet | ND | ND | ND | 36 PPI > 8 wks, 22 unkn meds or duration, 14 no meds | ND | ND | 21 failures (15%): 19 with recurrent symptoms, 2 had dysphagia | ND | ND | ND | 1 pt responding with PPI | ND | BMI not factor for success /failure | C
USA | | 143/138 | ND | | (n=80, off meds) | | | “pts seen up to 3 mo & every 6 mo”
Hospital | | | | | DeMeester
Case-control
Winslow 2003 | Nl BMI<25 | Nissen 90% | 47 | 51% Esophagitis | 51 | Majority of patients on medication | LES 10 mmHg | 35 mo | Reduced symptoms of heartburn, water brash, regurgitation; no difference between groups | ND | ND | ND | All groups had reduced requirement for meds | No difference between groups for number of return to work days; no difference for patient satisfaction | No difference for complications, reoperation, anatomical failure; overall improvement | C
USA | 82 (16%) | Toupet 10% | 28% male | 11% Barretts | | | 34% haital hernia*
University hospital | | 505/505 | | 15% Stricture
Cohort | Overweight BMI 25-29.9 | | 47 | 63% Esophagitis | 57 | | LES 9 mmHg
| 210 (42%) | | 69% male | 20% Barretts | | | 51% haital hernia
| | | | 17% Stricture
| Obese BMI ≥30 | | 48 | 53% Esophagitis | 59 (modified) | | LES 9 mmHg
| 212 (42%) | | 36% male | 12% Barretts | | | 47% haital hernia *p=0.03
| | | | 18% Stricture
Perez 2001 | Nl BMI<25 | Nissen | 47 | No | 100% abnl (Unkn # pts tested) | All pts symptomatic failures on meds, refused life-long meds, or had structural complications of GERD | Hiatal hernia: | 34 mo | Recurrences of 5.1%, 5.4%, 22.9% for nl, overweight, obese p=0.03 | ND | ND | ND | ND | ND | ND | C
USA | 78 (42%) | 187/187 | 53% male | 31 (17%) Barrett's | | | 86% none/small 14% >3 cm
University-based tertiary hospital | Overweight BMI 25-29.9
Cohort | 74 (40%)
| Obese BMI ≥30
| 35 (19%)
Khajanchee 2004 | ND | Nissen | 51 | 62% severe esophagitis | 93% abnl (off meds) | ND | 58% hiatal hernia | 8.8 mo | 89% had reduction or were symptom-free; weight not factor for symptomatic failure | ND | 9.7% abnl (133/193 asymptomatic tested) | ND | ND | ND | ND | C
USA | | 223/223 | 62% male | | DeMeester (>14.7)
Private center
Case-control
Blom 2002 | ND | Nissen | 48 med | 33 (20%) Stricture; 36 (22%) Barrett's | ND | ND | ND | 14 | Weight not factor for postop dysphagia | ND | ND | ND | ND | ND | ND | C
USA | | 163/103 | (15-78) | (Savary-Miller) | Abnl > 14.72) | | | mo
University hospital | | (preop dysphagia (n=60) excluded from analyses) | 73% male | | DeMeester | | | (med)
Case-control
Campos 1999 | Normal BMI 19-25: 47(24%) | Nissen | 49 med | 41% erosive esophagitis; 24% Barrett's | 86% (abnl >14.7, off meds) | Unknown meds/dose; response to acid suppression therapy: | 75% structurally defective LES; 70% hiatal hernia | 15 mo | 87% excellent/good & 13% poor symptomatic outcomes; weight not factor for outcomes | ND | ND | Unknown number of pts on meds | ND | ND | ND | C
USA | Overweight BMI 25-35: 144(72%) | 199/199 | (15-77) | | DeMeester | 7% complete
University hospital | Severely obese BMI>35: 8(4%) | | 70% male | | | 71% partial
Prospective cohort | | | | | | 17% minor
| | | | | | 5% none
Fraser 2001 | Normal BMI<25: 40(21%) | Nissen | 47 | ND | ND | ND | ND | 3.2 yr | Weight not factor for dysphagia; heartburn scores higher in normal weight group compared to overweight & obese groups p=0.001 | ND | ND | ND | ND | No difference in patient satisfaction between groups | ND | C
Austrialia | Overweight BMI 25-29.9: 88(45%) | 194/194 | (17-74)
University hospital | Obese BMI>30: 66(34%) | | 60% male
Ambi-directional cohort | Morbidly obese & obese groups combined

1 type of procedures not specified

Evidence Table 16. Psychological profile as modifying factor for outcomes after laparoscopic fundoplication

Author Yr | Pre-operative risk(s) assessed (R) | Intervention | Baseline patient characteristics | | | | | Follow-up duration | Status at follow up | | | | | | | Quality
Country | Psychological profile | Enrolled Final | Age | % ≥ grade 3 eophagitis | pH status | Responded to PPI or H2RA | EMS/Hiatal hernia | | Change in symptoms | Esophagitis status | pH status | Off PPI/ Off all anti-secretory meds | ↓ PPI dose or now responds to dose that failed before Rx | QOL/ satisfaction | EMS/ others
Setting | | | Sex
Study design
Velanovich 2001 | Major depression (5) Anxiety disorders (4), (diagnosed prior to surgical consult) | LAS 82% | ND | ND | ND | ND | ND | 6 wk | GERD-HRQL symptoms score for pt w/o vs with psychiatric disorders - 10.5 vs 1 | ND | ND | Most pts dissatisfied with symptomatic outcome restarted H2RA or PPIs | “Mixed results” | 11% psychiatric pt satisfied with surgery vs 95% for non-psychiatric pt p<0.000001 | Greater improvement for median total GERD-HRQL score for pt w/o vs with psychiatric disorders p<0.03 | C
USA | | Open anti-reflux fundoplication 18% | ND
University hospital | | 94/94
Retrospective cohort
Kamolz 2003 | Case: | Nissen 39% | 51 | 26% | 55 | Persistent or recurrent symptoms on 20-80 mg omeprazole @ day 18 mos | LES 3.1 mmHg | 1 yr | Significant improvement for both groups for heartburn, regurgitation, chest pain, bloating; Cases reported more chest pain, bloating, & dysphagia p<0.01 | ND | 100% normal, no difference between groups | No meds at 28 months follow-up | NA | GIQLI 99 for cases vs 122 controls p<0.05 | Normal LES - no difference between groups | C
Austria | Concomitant major depression | Toupet 61% | 37% male | more gr 0, fewer gr IV p<0.05 | DeMeester, Greater % dominant upright reflux p<0.05 | | 87% hiatal hernia
Public hospital | | 38/38
Matched case-control | Control: NA | Nissen 39% | 49 | 55% | 61 DeMeester | Persistent or recurrent symptoms on 20-80 mg omeprazole @ day 13 mos | LES 2.7 mmHg
| | Toupet 61% | 37% male | | | | 95% hiatal hernia
| | 38/38
Kamolz 2000 | Locus of control score: | Nissen | 51 | ND | 69 DeMeester (>17.5) | Persistent or recurrent symptoms on 20-80 mg omeprazole @ day 13.5 mos | LES 3.1 mmHg | 3 mos | Resolved for all pts | ND | 15.6 (nl < 17.5) 3 pts w/abnl score | ND | ND | GIQLI score 125 vs 92 at baseline | 2/87 abnl esophageal motility; LES 12 mmHg; | C
Austria | Internal 29.4 | 90/87 | 60% male | | | | | | Negative correlation for subjective dysphagia & internal control p<0.001 vs positive correlation for fatalistic external control p<0.01, significant between 2 traits | | | | | | Correlation for LES & subjective dysphagia, NS
Hospital | Social external 23.3
Cohort | Fatalistic external 22.6
| Factor of Reinforcement 27.1
| Scores within average range of comparable population
Power | 4 pts with varying issues from sexual abuse (1), depression (2), inorganic GI dysfunction (1) | Nissen | 43 | 48% esophagitis | 40 DeMeester | ND | ND | 71 mos | 117 were free of symptoms; 7 pt with symptom recurrence | ND, 13/14 in failed group had study | ND, 13/14 in failed group had study | 97% | ND | ND | Psychiatric history was significant factor in predicting failure p=0.002 | B
2004 | | 131/131 | 47% male | 7.6% Barrett's | | | | | | | | 127/131
UK
University hospital
Case-control

Evidence Table 17. Intraoperative complications (and those occurring within 30 days) for surgical and endoscopic procedures

| Surgical | | | | | | | | Endoscopic
| ONF | | LNF | | ONF /LNF | | LNF /LPA | | ECH | | ERX | | NDO plication | | STR
Mortality N (%) | Catarci 2004 | 0 | Coelho 2003 | 1(1.3) | Flum 2002 | 0 | Carlson 2001 | 8(<1) | Filipi 2001 | 0 | ND | | ND | | Triadafilopoulos 2002 | 0
| Parrilla 2003 | 0 | Catarci 2004 | 0 | | | | | | | | | | | Corley 2003 | 0
| | | Fernando 2002 | 0
| | | Mohan 2005 | 0
| | | Power 2004 | 0
Re-operation N(%) | ND | | O'Boyle 2000 | 3(<1) | ND | | ND | | ND | | ND | | ND | | Richards 2003 | 2(3.3)
Conversion N(%) | ND | | Catarci 2004 | 17(7.3) | ND | | Carlson 2001 | 271(3.1) | ND | | ND | | ND | | ND
| | | Leggett 2000 | 4(4)
| | | Power 2004 | 2(1.5)
| | | Coelho 2003
| | | Fernando 2002
GI injury /perforation N (%) | ND | | Leggett 2000 injury | 4(3.4) | Flum 2002 injury | 1,283 (1.4) | Richards 2003 enterotomy | 1(1.7) | Mahmood 2003 injury | 1(3.8) | Cohen 2003 | 0 | Pleskow 2004; 2005 perforation | 1(1.6) | Triadafilopoulos 2002; 2001 Injury perforation | 8 (6.8)
| | | Fernando 2002 perforation | 1(<1) | | | Walsh 2003 perforation | 3(1.2) | Filipi 2001 injury perforation | 2(3) | | | | 1(1.6) | Corley 2003 | 0
| | | Mohan 2005 injury | 1(<1) | | | Carlson 2001 injury | 62(<1) | Chadalavada 2004 injury perforation | 1(2) | | | | | | 0
| | | | | | | | | | 1(2)
| | | | | | | | | | 0
Pneumothorax N (%) | ND | | Chadalavada 2004 | 1(3) | ND | | Carlson 2001 | 67(<1) | ND | | ND | | Pleskow 2004; 2005 | 1 (1.6) | ND
| | | Coelho 2003 | 2(2.6)
| | | Fernando 2002 | 2(1.6)
| | | Leggett 2000 | 2(1.4)
Splenic injury N (%) | Parrilla 2003 splenectomy | 1(1.7) | Mohan 2005 | 2(1.8) | Flum 2002 splenectomy | 2065 (2.2) | Walsh 2003 | 1(<1) | ND | | ND | | ND | | ND
| | | Coelho 2003 | 1(1.3) | | | Carlson 2001 injury splenectomy | 16(<1)
| | | Sato 2002 | 1(<1) | | | | 4(<1)
Bleeding N(%) | ND | | Sato 2002 | 8(5) | ND | | Walsh 2003 | 2(<1) | Schiefke 2005 | 8(11) | ND | | ND | | DiBaise 2002 | 1(5.6)
| | | Coelho 2003 | 1(1.3) | | | Carlson 2001 | 49(<1) | Mahmood 2003 | 2(7.7) | | | | | Corley 2003 | 1(3)
| | | Leggett 2000 | 1(1) | | | | | Chen 2005 | 3(4.4)
| | | | | | | | | Filipi 2001 | 2(3)
| | | | | | | | | Chadalavada 2004 | 1(2)
| | | | | | | | | Tam 2004 | 0
Pulmonary N (%) | ND | | Fernando 2002 embolism | 3(2.5) | ND | | Walsh 2003 aspiration | 1 (<1) | Chadalavada 2004 aspiration | 2(4) | ND | | Pleskow 2004; 2005 dypsnea | 2(3.1) | ND
| | | | | | | Carlson 2001 embolism | 11 (<1) | Chen 2005 bronchospasm | 1(1.2)
| | | | | | | effusion | 12 (<1)
| | | | | | | atelectasis | 10 (<1)
Gastrointestinal N (%) | Parrilla 2003 inability to belch, vomit | 13 (22) | Seelig 1999 para-esophageal hernia /re-operation | 2(<1) | ND | | Carlson 2001 wrap herniation ulcer | 85(1.3) | ND | | ND | | Pleskow 2004; 2005 eructation | 9 (14) | Richards2003; 2001; Houston 2003 gastroparesis /esophagitis | 1 (4)
| | | Fernando 2002 gastric outlet obstruction gastric dilation | 1(<1) | | | Walsh 2003 acute recurrence hiatal hernia | 10(<1) | | | | | not specified | 11 (17)
| | | Anvari 2003;1996 esophageal leak | 1(<1) | | | pancreatitis | 1(<1)
| | | | 1(<1) | | | | 1(<1)
Infection/ Fever N (%) | ND | | Fernando 2002 pneumonia | 1(<1) | ND | | Carlson 2001 wound infection pneumonia abscess | 7(<1) | Abou-Rebyeh 2005 fever | 2(5.3) | ND | | ND | | Tam 2003 pain / mediastinitis | 1(3.8)
| | | wound infection | 1<1) | | | Walsh 2003 fever pneumonia | 37(<1) | Tam 2004 sepsis | 0 | | | | | Triadafilopoulos 2002 fever | 2(1.7)
| | | Power 2004 umbilical port site infection | 1(<1) | | | | 18(26)
| | | | | | | | 1(<1)
| | | | | | | | 1(<1)
Dysphagia N (%) | Parrilla 2003 | 17(29) | Coelho 2003 | 2(2.6) | ND | | Walsh 2003 | 6(3.6) | Mahmood 2003 | 2(7.7) | Cohen 2003 | 35(24) | Pleskow 2004; 2005 | 7(11) | Triadafilopoulos 2002; 2001 | 1(<1)
| | | | | | | | | Arts 2005 | 1(5) | Schumacher 2005 | 12(13)
| | | | | | | | | Chen 2005 | 1(1.2) | Deviere 2002 | 1(6.7)
Bloating N (%) | ND | | Power 2004 | 1(<1) | ND | | ND | | Mahmood 2003 | 2(7.7) | ND | | ND | | Corley 2003 | 1(3)
Nausea /vomiting N (%) | ND | | Chadalavada 2004 | 3(8) | ND | | ND | | Schiefke 2005 | 12(17) | ND | | Pleskow 2004; 2005 | 4(6) | ND
| | | | | | | | | Filipi 2001 | 9(14)
| | | | | | | | | Mahmood 2003 | 2(7.7)
| | | | | | | | | Chadalavada 2004 | 2(4)
| | | | | | | | | Abou-Rebyeh 2005 | 1(2.6)
Pain /discomfort N (%) | ND | | ND | | ND | | ND | | Schiefke 2005 retrosternal /pharyngeal | 58(83) | Deviere 2002 retrosternal | 8(53.3) | Pleskow 2004; 2005 abdominal chest | 13 (20) | Triadafilopoulos 2002; 2001 chest | 2(1.7)
| | | | | | | | | Mahmood 2003sore throat abdominal chest | 7(26.9) | | | epigastric | 11 (17) | discomfort with catheter passage | 22(19)
| | | | | | | | | Tam 2004 sore throat abdominal | 2(7.7) | | | | 1(1.6) | discomfort with RF energy delivery | 68(58)
| | | | | | | | | Filipi 2001 abdominal chest | 5(19.2) | | | | | Corley 2003 retrosternal | 4(11)
| | | | | | | | | Abou-Rebyeh 2005 | 4(26.7)
| | | | | | | | | Chadalavada 2004 | 0
| | | | | | | | | | 9(14)
| | | | | | | | | | 10(16)
| | | | | | | | | | 1(2.6)
| | | | | | | | | | 0
Other N (%) | ND | | Coelho 2003 acute delirium acute urinary retention acute ischemia lower extremity | 1(1.3) | ND | | Carlson 2001 myocardial infarction | 5(<1) | Chadalavada 2004 pharyngitis | 27(57) | ND | | Pleskow 2004; 2005 pharyngitis | 26 (41) | Triadafilopoulos 2002 submental swelling hypotension | 1(<1)
| | | Chadalavada 2004 urinary retention | 1(1.3) | | | trocar hernia | 12(<1) | Filipi 2001 pharyngitis | 20(31) | | | | | | 1(<1)
| | | Fernando 2002 atrial fibrillation dehydration | 1(1.3) | | | Walsh 2003 stroke | 1(<1) | Chadalavada 2004 hypoxia | 6(13)
| | | Mohan 2005 liver injury | 1(3) | | | deep venous thrombosis | 1(<1) | Filipi 2001 hypoxia | 4(6)
| | | Power 2004 port site hematoma urinary retention atrial fibrillation | 1(<1) | | | myocardial infarction | 1(<1) | Chen 2005 hypoxemia | 2(2.4)
| | | | 1(<1) | | | arrhythmia | 1(<1)
| | | | 1(<1) | | | | 1(<1)
| | | | 1(<1)
| | | | 1(<1)
| | | | 1(<1)

Carlson 2001: systematic review; 6,542 cases including 61.4% Nissen, 23.8% Toupet, 13.4% Nissen-Rossetti, and 1.4% other procedures; results on each procedure separately are not given

Catarci 2004: meta-analysis; peri-operative morbidity (not specified): 77(18%) for open Nissen, 32(10.4%) for Lap Nissen, 8(7.5%) for open Toupet, and 2(12.5%) for Lap Toupet

Flum 2002: two retrospective population-based cohort studies using the Washington State discharge database and the United States Health Care Utilization Project (HCUP) database; patients underwent Nissen fundoplication surgery: 86,411; the percentage of laparoscopic and open procedures is not specified

Arts 2005: Mild throat ache and mild epigastric pain were commonly observed immediately after the procedure (specific results not given)

Cohen 2003: it includes 8 patients with short-term dysphagia from Johnson 2003 study (2 publications: one with 6-mo follow-up and another with 12-mo follow-up)

O'Boyle 2000: specifically focused on patients with iagtrogenic stomach herniation as adverse event; other adverse events may have happened, as well but they were not reported

Seelig 1999: specifically focused on patients with para-esophageal hernia as adverse event; other adverse events may have happened, as well but they were not reported

Evidence Table 18. Complications occurring more than 30 days after surgical or endoscopic procedures

| Surgical | | | | | | | | | | Endoscopic
| ONF | | LNF | | OPA | | LPA | | LNF /LPA | | ERX | | STR
Re-operation N (%) | Catarci 2004 | 9 (3.4) | Catarci 2004 | 19 (5.6) | Catarci 2004 | 2 (2.2) | Ludemann 2005 | 3 (6) | ND | | ND | | ND
| | | Sato 2002 | 6 (4.3) | | | Catarci 2004 | 1 (1)
| | | O'Boyle 2000 | 6 (<1)
| | | Seelig 1999 | 4 (<1)
Bleeidng N (%) | ND | | ND | | ND | | ND | | ND | | ND | | Triadafilopoulos 2002 | 0
Gastrointestinal N (%) | ND | | Ludemann 2005 inability to belch normally | 22 (43) | ND | | Ludemann 2005 inability to belch normally | 10 (20) | Klaus 2003 diarrhea | 15 (17.9) | Cohen 2003 injury | 0 | Richards 2003; 2001; Houston 2003 pancreatitis | 1 (4)
| | | diarrhea | 14 (27) | | | diarrhea | 12 (24) | Carlson 2001 reflux | 206 (3.5) | | | Triadafilopoulos 2002; 2001 ulcer stricture | 0
| | | increased flatulence | 41 (80) | | | increased flatulence | 31 (62) | | | | | Torquati 2004 ulceration | 0
| | | Coelho 2003 ulcer | 2 (2.6) | | | | | | | | | | 0
| | | Dally 2004 penetration of Teflon pledgets | 7 (<1)
Dysphagia N (%) | Catarci 2004 | 42 (13.1) | Ludemann 2005 | 14 (27) | Catarci 2004 | 14 (13.2) | Ludemann 2005 | 9 (18) | Carlson 2001 | 188 (2.5) | Schumacher 2005 | 12 (13) | Triadafilopoulos 2002; 2001 | 0
| | | Catarci 2004 | 55 (15.1) | | | Catarci 2004 | 6 (5.2) | Richards 2003 | 0 | Johnson 2003 | 8 (10.3) | Lufti 2005; Torquati 2004 | 0
| | | Sato 2002 | 9 (6.5) | | | | | | | Cohen 2003 | 1 (<1)
| | | Mahon 2005 | 5 (4.6)
Bloating N (%) | Catarci 2004 | 24 (12.8) | Ludemann 2005 | 38 (75) | ND | | Ludemann 2005 | 22 (44) | Klaus 2003 | 16 (19) | ND | | Lufti 2005 | 0
| | | Anvari 2001; 1998 | 45 (32) | | | | | Carlson 2001 | 239 (9.4)
| | | Catarci 2004 | 23 (12.2) | | | | | Richards 2003 | 0
| | | Coelho 2003 | 6 (7.8)
Pain N (%) | ND | | ND | | ND | | ND | | ND | | ND | | Triadafilopoulos 2002 chest | 0

Carlson 2001: systematic review; 6,542 cases including 61.4% Nissen, 23.8% Toupet, 13.4% Nissen-Rossetti, and 1.4% other procedures; results on each procedure separately are not given

Catarci 2004: meta-analysis

Dally 2004: specifically focused on patients with symptomatic lumenal penetration of Teflon pledgets as adverse event; other adverse events may have happened, as well but they were not reported; some of these patients were re-operated for that complication (specific number could not be extracted)

O'Boyle 2000: specifically focused on patients with iagtrogenic stomach herniation as adverse event; other adverse events may have happened, as well but they were not reported

Seelig 1999: specifically focused on patients with para-esophageal hernia as adverse event; other adverse events may have happened, as well but they were not reported

Evidence Table 19. Complications of uncertain time period occurring after surgical and endoscopic procedures

| Surgical | | Endoscopic
| LNF | LNF /LPA | ERX
Mortality N (%) | ND | Walsh 2003 1(<1) | ND
Re-operation N (%) | Mahon 2005 4(3.7) | Sandbu 2002 18 (4.4) | ND
| Bammer 2001 5(2.9) | Walsh 2003 8 (3)
| Leggett 2000 2(2) | Carlson 2001 162 (2.7)
| Fernando 2002 2(1.7)
| Anvari 2003; 1996 5 (1.5)
Pulmonary N (%) | Legget 2000 | ND | Schumacher 2005
| Atelectasis: 4 (1.6) | | Effusion: 1 (1.1)
GI N (%) | Fernando 2002 | Sandbu 2002 | Johnson 2003
| Diarrhea 21 (12.3) | Difficult to vomit 193 (47.3) | Nausea /vomiting 12 (14.1)
| Leggett 2000 | Difficult or unable to belch 154 (37.7) | Schumacher 2005
| Ileus: 1 (1) | Klaus 2003 | Belching 6 (7.1)
| | Constipation 3 (2.8) | Regurgitation 1 (1.1)
| | | Deviere 2005
| | | Belching 1 (3.1)
Infection/ Fever N (%) | Mohan 2005 | Chadalavada 2004 | Schumacher 2005
| Respiratory tract infection: 2 (1.8) | Gastrostomy tube site infection: 1 (3) | Fever 24 (26)
| Leggett 2000 | | Deviere 2005
| Pneumonia: 1 (<1) | | Fever 7 (21.9)
| Mediastenitis: 1 (<1) | | Johnson 2003
| | | Fever 10 (11.8)
Dysphagia N (%) | Power 2004 131 (100) | Sandbu 2002 32 (7.8) | Deviere 2005 9 (28.1)
| Sato 2002 33 (24) | Chadalavada 2004 20 (51) | Schumacher 2005 12 (13)
| Fernando 2002 21(18) | Walsh 2003 67 (25.2)
| Bammer 2001 21(12.5)
| Blom 2002 8(4.9)
| Coelho 2003 2 (2.6)
Bloating N (%) | Fernando 2002 54 (46) | Sandbu 2002 145 (35.5) | Johnson 2003 5 (5.9)
| Bammer 2001 35 (20.5) | Walsh 2003 2 (<1) | Deviere 2005 1(1.3)
| | | Schumacher 2005 1 (1.1)
Pain /discomfort N (%) | ND | Chadalavada 2004 | Cohen 2005
| | Chest: 12 (30) | Retrosternal 122 (85)
| | Klaus 2003 | Schumacher 2005
| | Abdominal: 6 (5.5) | Chest 72(77)
| | | Johnson 2003
| | | Shoulder: 3 (3.5)
| | | Rib: 1 (1.2)
| | | Breast: 1 (1.2)
| | | Deviere 2005
| | | Retrosternal /epigastric 22 (68.8)
Other N (%) | Bammer 2001 | Walsh 2003 | Schumacher 2005
| Trocar wound problems /scars: 10 (6) | Recurrent hiatal hernia: 9 (3.4) | Flu syndrome: 1 (1.1)
| Leggett 2000 | Richards 2003 | Bradycardia: 1 (1.1)
| Atrial fibrillation: 1 (<1) | Incisional hernia: 2 (3.3) | Johnson 2003
| Biloma: 1 (<1) | | Pharyngitis: 9 (10.6)
| | | Body odor /bad taste: 4 (4.7)
| | | Dry mouth: 2 (2.4)
| | | Anxiety: 2 (2.4)
| | | Flu syndrome: 1 (1.2)

Carlson 2001: systematic review; 6,542 cases including 61.4% Nissen, 23.8% Toupet, 13.4% Nissen-Rossetti, and 1.4% other procedures; results on each procedure separately are not given