# List of Excluded Studies

## List of Excluded Studies

Abbas AE, Deschamps C, Cassivi SD, Allen MS, Nichols FC, Miller DL, Pairolero PC. Barrett's esophagus: the role of laparoscopic fundoplication. Feb. Annals of Thoracic Surgery. 2004;77(2):393-6. Outcome not of interest. [pmid: 14759403].
Ackroyd R, Watson DI, Majeed AW, Troy G, Treacy PJ, Stoddard CJ. Randomized clinical trial of laparoscopic versus open fundoplication for gastro-oesophageal reflux disease.[see comment]. Aug. British Journal of Surgery. 2004;91(8):975-82. Does not meet inclusion criteria. [pmid: 15286957].
Alexander HC, Hendler RS, Seymour NE, Shires GT. Laparoscopic treatment of gastroesophageal reflux disease. May. American Surgeon. 1997;63(5):434-40. Does not meet inclusion criteria. [pmid: 9128233].
Alexiou C, Beggs D, Salama FD, Beggs L, Knowles KR. A tailored surgical approach for gastro-oesophageal reflux disease: the Nottingham experience. Apr. European Journal of Cardio-Thoracic Surgery. 2000;17(4):389-95. Does not meet inclusion criteria. [pmid: 10773560].
Alexiou C, Salama FD, Beggs D, Brackenbury ET, Knowles KR. Comparison of long-term results of total fundoplication gastroplasty and Belsey Mark IV antireflux operations in relation to the severity of oesophagitis. Mar. European Journal of Cardio-Thoracic Surgery. 1999;15(3):320-6. Technique not of interest. [pmid: 10333030].
Allen CJ, Anvari M. Gastro-oesophageal reflux related cough and its response to laparoscopic fundoplication. Nov. Thorax. 1998;53(11):963-8. Does not meet inclusion criteria. [pmid: 10193396]. [pmcid: 1745120].
Allescher HD, Bockenhoff A, Knapp G, Wienbeck M, Hartung J. Treatment of non-ulcer dyspepsia: a meta-analysis of placebo-controlled prospective studies.[see comment]. Sep. Scandinavian Journal of Gastroenterology. 2001;36(9):934-41. Population not of interest. [pmid: 11521983].
Allgood PC, Bachmann M. Medical or surgical treatment for chronic gastrooesophageal reflux? A systematic review of published evidence of effectiveness. Sep. European Journal of Surgery. 2000;166(9):713-21. Poor quality. [pmid: 11034468].
Althar RA. Laparoscopic anti-reflux surgery in the community hospital setting: evaluation of 100 consecutive patients. Apr. Journal of the Society of Laparoendoscopic Surgeons. 1999;3(2):107-12. Does not meet inclusion criteria. [pmid: 10444008].
Anderson JA, Myers JC, Watson DI, Gabb M, Mathew G, Jamieson GG. Concurrent fluoroscopy and manometry reveal differences in laparoscopic Nissen and anterior fundoplication. Apr. Digestive Diseases & Sciences. 1998;43(4):847-53. Does not meet inclusion criteria. [pmid: 9558043].
Anvari M, Allen C, Borm A. Laparoscopic Nissen fundoplication is a satisfactory alternative to long-term omeprazole therapy. Jul. British Journal of Surgery. 1995;82(7):938-42. Does not meet inclusion criteria. [pmid: 7648115].
Anvari M, Allen C, Moran LA. Immediate and delayed effects of laparoscopic Nissen fundoplication on pulmonary function. Dec. Surgical Endoscopy. 1996;10(12):1171-5. Does not meet inclusion criteria. [pmid: 8939836].
Arca MJ, Gagner M, GarciaRuiz A, Todd HB. The significance of pH and manometric testing after laparoscopic fundoplication.[see comment]. Mar. Surgical Endoscopy. 2002;16(3):395-400. Outcome not of interest. [pmid: 11928015].
Attwood SE, Barlow AP, Norris TL, Watson A. Barrett's oesophagus: effect of antireflux surgery on symptom control and development of complications. Oct. British Journal of Surgery. 1992;79(10):1050-3. Does not meet inclusion criteria. [pmid: 1422717].
Battle WS, Nyhus LM, Bombeck CT. Nissen fundoplication and esophagitis secondary to gastroesophageal reflux. Apr. Archives of Surgery. 1973;106(4):588-92. Does not meet inclusion criteria. [pmid: 4696733].
Bell RC, Hanna P, Powers B, Sabel J, Hruza D. Clinical and manometric results of laparoscopic partial (Toupet) and complete (Rosetti-Nissen) fundoplication. Jul. Surgical Endoscopy. 1996;10(7):724-8. Does not meet inclusion criteria. [pmid: 8662427].
Bensoussan AL, Yazbeck S, Carceller Blanchard A. Results and complications of Toupet partial posterior wrap: 10 years' experience. Sep. Journal of Pediatric Surgery. 1994;29(9):1215-7. Pediatrics. [pmid: 7807348].
Bischof G, Feil W, Riegler M, Wenzl E, Schiessel R. Peptic esophageal stricture: is surgery still necessary?. Wiener Klinische Wochenschrift. 1996;108(9):267-71. Population not of interest. [pmid: 8686319].
Bisgaard T, Stockel M, Klarskov B, Kehlet H, Rosenberg J. Prospective analysis of convalescence and early pain after uncomplicated laparoscopic fundoplication. Nov. British Journal of Surgery. 2004;91(11):1473-8. Outcome not of interest. [pmid: 15386321].
Blomqvist A, Dalenback J, Hagedorn C, Lonroth H, Hyltander A, Lundell L. Impact of complete gastric fundus mobilization on outcome after laparoscopic total fundoplication. Sep. Journal of Gastrointestinal Surgery. 2000;4(5):493-500. Does not meet inclusion criteria. [pmid: 11077325].
Blomqvist A, Lonroth H, Dalenback J, Ruth M, Wiklund I, Lundell L. Quality of life assessment after laparoscopic and open fundoplications. Results of a prospective, clinical study. Nov. Scandinavian Journal of Gastroenterology. 1996;31(11):1052-8. Does not meet inclusion criteria. [pmid: 8938896].
Bloomston M, Nields W, Rosemurgy AS. Symptoms and antireflux medication use following laparoscopic Nissen fundoplication: outcome at 1 and 4 years.[erratum appears in JSLS. 2003 Oct-Dec;7(4):388]. Jul. Journal of the Society of Laparoendoscopic Surgeons. 2003;7(3):211-8. Does not meet inclusion criteria. [pmid: 14558708].
Bloomston M;Zervos E;Gonzalez R;Albrink M;Rosemurgy A;Quality of life and antireflux medication use following laparoscopic Nissen fundoplication 1998 Jun American Surgeon 64(6):509–13; discussion 513–4,Does not meet inclusion criteria
Blum AL;Treatment of acid-related disorders with gastric acid inhibitors: the state of the art 1990Digestion 47 Suppl 1:3–10; discussion 49–52,Data available in systematic review
Booth MI, Stratford J, Thompson E, Dehn TC. Laparoscopic antireflux surgery in the treatment of the acid-sensitive oesophagus. Apr. British Journal of Surgery. 2001;88(4):577-82. Does not meet inclusion criteria. [pmid: 11298628].
Boutelier P, Jonsell G. An alternative fundoplicative maneuver for gastroesophageal reflux. Feb. American Journal of Surgery. 1982;143(2):260-4. Does not meet inclusion criteria. [pmid: 7058999].
Bowes KL, Sarna SK. Effect of fundoplication on the lower esophageal sphincter. Jul. Canadian Journal of Surgery. 1975;18(4):328-33. Outcome not of interest.
Bowes KL, Sarna SK. Effect of fundoplication on the lower esophageal sphincter. Jul. Canadian Journal of Surgery. 1975;18(4):328-33. Outcome not of interest.
Brand DL, Eastwood IR, Martin D, Carter WB, Pope CE. Esophageal symptoms, manometry, and histology before and after antireflux surgery: a long-term follow-up study. Jun. Gastroenterology. 1979;76(6):1393-401. Does not meet inclusion criteria. [pmid: 437437].
Brouwer R, Kiroff GK. Improvement of respiratory symptoms following laparoscopic Nissen fundoplication. Apr. ANZ Journal of Surgery. 2003;73(4):189-93. Does not meet inclusion criteria. [pmid: 12662224].
Brunner G;Creutzfeldt W;Omeprazole in the long-term management of patients with acid-related diseases resistant to ranitidine 1989Scandinavian Journal of Gastroenterology - Supplement 166:101–5; discussion 111–3,Available meta-analysis
Bushkin FL, Neustein CL, Parker TH, Woodward ER. Nissen fundoplication for reflux peptic esophagitis. Jun. Annals of Surgery. 1977;185(6):672-7. Does not meet inclusion criteria. [pmid: 871221]. [pmcid: 1396217].
Byrne WJ, Euler AR, Ashcraft E, Nash DG, Seibert JJ, Golladay ES. Gastroesophageal reflux in the severely retarded who vomit: criteria for and results of surgical intervention in twenty-two patients. Jan. Surgery. 1982;91(1):95-8. Does not meet inclusion criteria. [pmid: 7054912].
Cadiere GB, Himpens J, Rajan A, Muls V, Lemper JC, Bruyns J, Urbain D, Ham H. Laparoscopic Nissen fundoplication: laparoscopic dissection technique and results. Jan. Hepato-Gastroenterology. 1997;44(13):4-10. Does not meet inclusion criteria. [pmid: 9058110].
Cadiere GB, Himpens J, Vertruyen M, Bruyns J, Germay O, Leman G, Izizaw R. Evaluation of telesurgical (robotic) NISSEN fundoplication. Sep. Surgical Endoscopy. 2001;15(9):918-23. Surgical technique description. [pmid: 11605106].
Champault G, Volter F, Rizk N, Boutelier P. Gastroesophageal reflux: conventional surgical treatment versus laparoscopy. A prospective study of 61 cases. Dec. Surgical Laparoscopy & Endoscopy. 1996;6(6):434-40. Does not meet inclusion criteria. [pmid: 8948034].
Chiba N, De Gara CJ, Wilkinson JM, Hunt RH. Speed of healing and symptom relief in grade II to IV gastroesophageal reflux disease: a meta-analysis. Jun. Gastroenterology. 1997;112(6):1798-810. Data available in subsequent meta-analysis. [pmid: 9178669].
Chrysos E, Athanasakis E, Pechlivanides G, Tzortzinis A, Mantides A, Xynos E. The effect of total and anterior partial fundoplication on antireflux mechanisms of the gastroesophageal junction. Jul. American Journal of Surgery. 2004;188(1):39-44. Does not meet inclusion criteria. [pmid: 15219483].
Chrysos E, Prokopakis G, Athanasakis E, Pechlivanides G, Tsiaoussis J, Mantides A, Xynos E. Factors affecting esophageal motility in gastroesophageal reflux disease. Mar. Archives of Surgery. 2003;138(3):241-6. Outcome not of interest. [pmid: 12611566].
Chrysos E, Tsiaoussis J, Zoras OJ, Athanasakis E, Mantides A, Katsamouris A, Xynos E. Laparoscopic surgery for gastroesophageal reflux disease patients with impaired esophageal peristalsis: total or partial fundoplication?. Journal of the American College of Surgeons. 2003;197(1):8-15. Does not meet inclusion criteria. [pmid: 12831918].
Cicala M, Gabbrielli A, Emerenziani S, Guarino MP, Ribolsi M, Caviglia R, Costamagna G. Effect of endoscopic augmentation of the lower oesophageal sphincter (Gatekeeper reflux repair system) on intraoesophageal dynamic characteristics of acid reflux.[see comment]. Feb. Gut. 2005;54(2):183-6. Gatekeeper not available in US. [pmid: 15647177]. [pmcid: 1774830].
Civello IM, Brisinda G, Sganga G, De Fazio S, Maria G, Crucitti F. Modified Hill operation vs. Nissen fundoplication in the surgical treatment of gastro-esophageal reflux disease. Mar. Hepato-Gastroenterology. 1997;44(14):380-6. Intervention not of interest. [pmid: 9164506].
Coelho JC, Wiederkehr JC, Campos AC, Andrigueto PC. Conversions and complications of laparoscopic treatment of gastroesophageal reflux disease. Oct. Journal of the American College of Surgeons. 1999;189(4):356-61. Mixed surgeries. [pmid: 10509460].
Cohen JA, Arain A, Harris PA, Byrne DW, Holzman MD, Sharp KW, Richards WO. Surgical trial investigating nocturnal gastroesophageal reflux and sleep (STINGERS). Mar. Surgical Endoscopy. 2003;17(3):394-400. Does not meet inclusion criteria. [pmid: 12436237].
Contini S, Bertele A, Nervi G, Zinicola R, Scarpignato C. Quality of life for patients with gastroesophageal reflux disease 2 years after laparoscopic fundoplication. Evaluation of the results obtained during the initial experience.[see comment]. Nov. Surgical Endoscopy. 2002;16(11):1555-60. Does not meet inclusion criteria. [pmid: 12072998].
Contini S, Bertele A, Nervi G, Zinicola R, Scarpignato C. Quality of life for patients with gastroesophageal reflux disease 2 years after laparoscopic fundoplication. Evaluation of the results obtained during the initial experience.[see comment]. Nov. Surgical Endoscopy. 2002;16(11):1555-60. Does not meet inclusion criteria. [pmid: 12072998].
Contini S, Zinicola R, Bertele A, Nervi G, Rubini P, Scarpignato C. Dysphagia and clinical outcome after laparoscopic Nissen or Rossetti fundoplication: sequential prospective study. Sep. World Journal of Surgery. 2002;26(9):1106-11. Does not meet inclusion criteria. [pmid: 12045866].
Coster DD, Bower WH, Wilson VT, Brebrick RT, Richardson GL. Laparoscopic partial fundoplication vs laparoscopic Nissen-Rosetti fundoplication. Short-term results of 231 cases.[see comment]. Jun. Surgical Endoscopy. 1997;11(6):625-31. Does not meet inclusion criteria. [pmid: 9171120].
Coster DD, Bower WH, Wilson VT, Butler DA, Locker SC, Brebrick RT. Laparoscopic Nissen fundoplication--a curative, safe, and cost-effective procedure for complicated gastroesophageal reflux disease. Apr. Surgical Laparoscopy & Endoscopy. 1995;5(2):111-7. Does not meet inclusion criteria. [pmid: 7773455].
Cremonini F;Di Caro S;DelgadoAros S;Sepulveda A;Gasbarrini G;Gasbarrini A;Camilleri M;Meta-analysis: the relationship between Helicobacter pylori infection and gastro-oesophageal reflux disease.[retraction in Cremonini F, Di Caro S, Delgado-Aros S, Sepulveda A, Gasbarrini G, Gasbarrini A, Camilleri M. Aliment Pharmacol Ther. 2004 Jan 1;19(1):145; PMID: 14687178] 2003 Aug 1 Alimentary Pharmacology & Therapeutics 18(3):279–89,Intervention not of interest
Csendes A, Burdiles P, Korn O, Braghetto I, Huertas C, Rojas J. Late results of a randomized clinical trial comparing total fundoplication versus calibration of the cardia with posterior gastropexy. Mar. British Journal of Surgery. 2000;87(3):289-97. Intervention not of interest. [pmid: 10718796].
Dallemagne B, Weerts JM, Jeahes C, Markiewicz S. Results of laparoscopic Nissen fundoplication. Sep. Hepato-Gastroenterology. 1998;45(23):1338-43. Does not meet inclusion criteria. [pmid: 9840062].
Dallemagne B, Weerts JM, Jehaes C, Markiewicz S. Causes of failures of laparoscopic antireflux operations. Mar. Surgical Endoscopy. 1996;10(3):305-10. Does not meet inclusion criteria. [pmid: 8779064].
Dassinger MS;Torquati A;Houston HL;Holzman MD;Sharp KW;Richards WO;Laparoscopic fundoplication: 5-year follow-up 2004 Aug American Surgeon 70(8):691–4; discussion 694–5,Does not meet inclusion criteria
de Beaux AC, Watson DI, O'Boyle C, Jamieson GG. Role of fundoplication in patient symptomatology after laparoscopic antireflux surgery. Aug. British Journal of Surgery. 2001;88(8):1117-21. Descriptive study. [pmid: 11488799].
de Jong JR, van Ramshorst B, Timmer R, Gooszen HG, Smout AJ. The influence of laparoscopic adjustable gastric banding on gastroesophageal reflux. Mar. Obesity Surgery. 2004;14(3):399-406. Does not meet inclusion criteria. [pmid: 15072663].
DeMeester TR;Bonavina L;Albertucci M;Nissen fundoplication for gastroesophageal reflux disease. Evaluation of primary repair in 100 consecutive patients 1986Annals of SurgeryDoes not meet inclusion criteria
DeMeester TR, Johnson LF. Evaluation of the Nissen antireflux procedure by esophageal manometry and twenty-four hour pH monitoring. Jan. American Journal of Surgery. 1975;129(1):94-100. Does not meet inclusion criteria. [pmid: 2024].
Demos NJ. Stapled, uncut gastroplasty for hiatal hernia: 12-year follow-up. Oct. Annals of Thoracic Surgery. 1984;38(4):393-9. Intervention not of interest. [pmid: 6385891].
Desai KM, Soper NJ, Frisella MM, Quasebarth MA, Dunnegan DL, Brunt LM. Efficacy of laparoscopic antireflux surgery in patients with Barrett's esophagus. Dec. American Journal of Surgery. 2003;186(6):652-9. Outcome not of interest. [pmid: 14672774].
DeVault KR. Surgery versus medical therapy for gastroesophageal reflux disease. Jun. American Journal of Gastroenterology. 2001;96(6):1932-3. Comment. [pmid: 11419855].
Dobrilla G, Comberlato M, Steele A, Vallaperta P. Drug treatment of functional dyspepsia. A meta-analysis of randomized controlled clinical trials. Apr. Journal of Clinical Gastroenterology. 1989;11(2):169-77. Population not of interest. [pmid: 2567747].
Donahue PE, Samelson S, Nyhus LM, Bombeck CT. The floppy Nissen fundoplication. Effective long-term control of pathologic reflux. Jun. Archives of Surgery. 1985;120(6):663-8. Does not meet inclusion criteria. [pmid: 4004552].
Edwards SJ, Lind T, Lundell L. Systematic review of proton pump inhibitors for the acute treatment of reflux oesophagitis. Nov. Alimentary Pharmacology & Therapeutics. 2001;15(11):1729-36. Limited individual comparisons (only esomeprazole vs. omeprazole). [pmid: 11683686].
Ellingson TL;Kozarek RA;Gelfand MD;Botoman AV;Patterson DJ;Iatrogenic achalasia. A case series 1995 Journal of Clinical GastroenterologyPopulation not of interest
Erenoglu C, Miller A, Schirmer B. Laparoscopic Toupet versus Nissen fundoplication for the treatment of gastroesophageal reflux disease. Oct. International Surgery. 2003;88(4):219-25. Does not meet inclusion criteria. [pmid: 14717528].
Eriksson S, Langstrom G, Rikner L, Carlsson R, Naesdal J. Omeprazole and H2-receptor antagonists in the acute treatment of duodenal ulcer, gastric ulcer and reflux oesophagitis: a meta-analysis.[erratum appears in Eur J Gastroenterol Hepatol 1996 Feb;8(2):192]. May. European Journal of Gastroenterology & Hepatology. 1995;7(5):467-75. Data available in subsequent systematic review. [pmid: 7614110].
Eshraghi N, Farahmand M, Soot SJ, RandLuby L, Deveney CW, Sheppard BC. Comparison of outcomes of open versus laparoscopic Nissen fundoplication performed in a single practice. May. American Journal of Surgery. 1998;175(5):371-4. Does not meet inclusion criteria. [pmid: 9600280].
Ettinger;Paul RE;Moran JM;Gastric pseudotumor after fundoplication 1971 Sep Gastroenterology 61(3):299–304, Outcome not of interest
Feldman LS;Mayrand S;Stanbridge D;Mercier L;Barkun JS;Fried GM;Laparoscopic fundoplication: a model for assessing new technology in surgical procedures 2001 Oct Surgery 130(4):686–93; discussion 693–5, Does not meet inclusion criteria
Feretis C, Benakis P, Dimopoulos C, Dailianas A, Filalithis P, Stamou KM, Manouras A, Apostolidis N. Endoscopic implantation of Plexiglas (PMMA) microspheres for the treatment of GERD.[see comment]. Apr. Gastrointestinal Endoscopy. 2001;53(4):423-6. Multiple reasons. [pmid: 11275880].
Field SK, Sutherland LR. Does medical antireflux therapy improve asthma in asthmatics with gastroesophageal reflux?: a critical review of the literature. Jul. Chest. 1998;114(1):275-83. Outcome: asthma symptoms. [pmid: 9674479].
Finney JS, Kinnersley N, Hughes M, O'BryanTear CG, Lothian J. Meta-analysis of antisecretory and gastrokinetic compounds in functional dyspepsia. Jun. Journal of Clinical Gastroenterology. 1998;26(4):312-20. Population not of interest. [pmid: 9649020].
Fockens P, Bruno MJ, Gabbrielli A, Odegaard S, Hatlebakk J, Allescher HD, Rosch T, Rhodes M, Bastid C, Rey J, Boyer J, Muehldorffer S, van den HU, Costamagna G. Endoscopic augmentation of the lower esophageal sphincter for the treatment of gastroesophageal reflux disease: multicenter study of the Gatekeeper Reflux Repair System. Aug. Endoscopy. 2004;36(8):682-9. Intervention not of interest. [pmid: 15280972].
Fouad YM, Katz PO, Castell DO. Oesophageal motility defects associated with nocturnal gastro-oesophageal reflux on proton pump inhibitors. Nov. Alimentary Pharmacology & Therapeutics. 1999;13(11):1467-71. Does not meet inclusion criteria. [pmid: 10571603].
Frantzides CT, Carlson MA. Laparoscopic versus conventional fundoplication. Jun. Journal of Laparoendoscopic Surgery. 1995;5(3):137-43. Does not meet inclusion criteria. [pmid: 7548986].
Frantzides CT;Richards C;A study of 362 consecutive laparoscopic Nissen fundoplications 1998 Oct Surgery 124(4):651–4; discussion 654–5, Does not meet inclusion criteria
Franzen T, Anderberg B, Tibbling GL, Johansson KE. Prospective evaluation of laparoscopic and open 360 degree fundoplication in mild and severe gastro-oesophageal reflux disease. European Journal of Surgery. 2002;168(10):539-45. Does not meet inclusion criteria. [pmid: 12666693].
Gadenstatter M, Wykypiel H, Schwab GP, et al. Respiratory symptoms and dysphagia in patients with gastroesophageal reflux disease: a comparison of medical and surgical therapy. DecLangenbecks Archives of Surgery. 1999;384(6):563-7. Multiple reasons complicated GERD.
Galvani C;Fisichella PM;Gorodner MV;Perretta S;Patti MG;Symptoms are a poor indicator of reflux status after fundoplication for gastroesophageal reflux disease: role of esophageal functions tests 2003 May Archives of Surgery 138(5):514–8; discussion 518–9, Does not meet inclusion criteria
Gibson PGGastro-oesophageal reflux treatment for asthma in adults and children 2005 Cochrane Database Extra-esophageal GERD outcomes
Gill RC, Bowes KL, Murphy PD, Kingma YJ. Esophageal motor abnormalities in gastroesophageal reflux and the effects of fundoplication. Aug. Gastroenterology. 1986;91(2):364-9. Outcome not of interest. [pmid: 3721123].
Glise H;Hallerback B;Johansson B;Quality of Life assessments in the evaluation of gastroesophageal reflux and peptic ulcer disease before, during and after treatment 1995 Scandinavian Journal of Gastroenterology - Supplement Does not meet inclusion criteria
Granderath FA, Kamolz T, Schweiger UM, Pointner R. Laparoscopic antireflux surgery for gastroesophageal reflux disease: experience with 668 laparoscopic antireflux procedures. Jan. International Journal of Colorectal Disease. 2003;18(1):73-7. Does not meet inclusion criteria. [pmid: 12458385].
Gundermann KJ;Godehardt E;Ulbrich M;Efficacy of a herbal preparation in patients with functional dyspepsia: a meta-analysis of double-blind, randomized, clinical trials 2003 Advances in Therapy Population: non-ulcer dyspepsia; intervention: not H2-blocker or PPI
Hage E, Hendel L, Gustafsen J, Hendel J. Histopathology of the gastric oxyntic mucosa in two different patient groups during long-term treatment with omeprazole. Jul. European Journal of Gastroenterology & Hepatology. 2003;15(7):781-9. All med tx before systematic review. [pmid: 12811309].
Hagedorn C, Jonson C, Lonroth H, Ruth M, Thune A, Lundell L. Efficacy of an anterior as compared with a posterior laparoscopic partial fundoplication: results of a randomized, controlled clinical trial. Aug. Annals of Surgery. 2003;238(2):189-96. Does not meet inclusion criteria. [pmid: 12894011]. [pmcid: 1422692].
Hailey D;Endoscope-based treatments for gastroesophageal reflux disease 2004 Mar Issues in Emerging Health Technologies (54):1–4, Poor quality
Halabi A, Kirch W. Cardiovascular effects of omeprazole and famotidine. Sep. Scandinavian Journal of Gastroenterology. 1992;27(9):753-6. No Adverse events. [pmid: 1411281].
Hasselgren G, HassanAlin M, Andersson T, ClaarNilsson C, Rohss K. Pharmacokinetic study of esomeprazole in the elderly. Clinical Pharmacokinetics. 2001;40(2):145-50. No Adverse events. [pmid: 11286324].
Henderson RD, Marryatt G. Total fundoplication gastroplasty. Long-term follow-up in 500 patients. Jan. Journal of Thoracic & Cardiovascular Surgery. 1983;85(1):81-7. Does not meet inclusion criteria. [pmid: 6848890].
Hillman AL, Bloom BS, Fendrick AM, Schwartz JS. Cost and quality effects of alternative treatments for persistent gastroesophageal reflux disease. Jul. Archives of Internal Medicine. 1992;152(7):1467-72. Outcome not of interest. [pmid: 1627026].
Hillman LC, Chiragakis L, Shadbolt B, Kaye GL, Clarke AC. Proton-pump inhibitor therapy and the development of dysplasia in patients with Barrett's oesophagus.[see comment]. Apr. Medical Journal of Australia. 2004;180(8):387-91. Outcome not of interest. [pmid: 15089728].
Hofstetter WL;Peters JH;DeMeester TR;Hagen JA;DeMeester SR;Crookes PF;Tsai P;Banki F;Bremner CG; Long-term outcome of antireflux surgery in patients with Barrett's esophagus 2001 Oct Annals of Surgery 234(4):532–8; discussion 538–9, Outcome not of interest
Houston H, Khaitan L, Holzman M, Richards WO. First year experience of patients undergoing the Stretta procedure. Mar. Surgical Endoscopy. 2003;17(3):401-4. Data available in a long-term study (Lutfu 2005). [pmid: 12436238].
Hunter JG;Smith CD;Branum GD;Waring JP;Trus TL;Cornwell M;Galloway K;Laparoscopic fundoplication failures: patterns of failure and response to fundoplication revision 1999 Oct Annals of Surgery 230(4):595–604; discussion 604–6, Does not meet inclusion criteria
Hunter JG, Swanstrom L, Waring JP. Dysphagia after laparoscopic antireflux surgery. The impact of operative technique.[see comment]. Jul. Annals of Surgery. 1996;224(1):51-7. Outcome not of interest. [pmid: 8678618]. [pmcid: 1235246].
Incarbone R;Bonavina L;Reitano M;Peracchia A;Esophageal function studies in the management of gastroesophageal reflux disease 1999 International Journal of Surgical Investigation 1(4):351–6, Does not meet inclusion criteria
Jaakkimainen RL, Boyle E, Tudiver F. Is Helicobacter pylori associated with non-ulcer dyspepsia and will eradication improve symptoms? A meta-analysis.[see comment]. Oct. 16 BMJ. 1999;319(7216):1040-4. Population: non-ulcer dyspepsia. [pmid: 10521198]. [pmcid: 28257].
Jobe BA, Wallace J, Hansen PD, Swanstrom LL. Evaluation of laparoscopic Toupet fundoplication as a primary repair for all patients with medically resistant gastroesophageal reflux. Nov. Surgical Endoscopy. 1997;11(11):1080-3. Does not meet inclusion criteria. [pmid: 9348378].
Joelson S;Joelson IB;Lundborg P;Walan A;Wallander MA; Safety experience from long-term treatment with omeprazole.[erratum appears in Digestion 1992;53(3–4):213]1992Digestion 51 Suppl 1:93–101, Data available in meta-analysis
Kamolz T, Granderath FA, Pointner R. The outcome of laparoscopic antireflux surgery in relation to patients' subjective degree of compliance with former antireflux medication. Jun. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2003;13(3):155-60. Does not meet inclusion criteria.
KaplanMachlis B, Spiegler GE, Revicki DA. Health-related quality of life in primary care patients with gastroesophageal reflux disease. Oct. Annals of Pharmacotherapy. 1999;33(10):1032-6. Outcome not of interest. [pmid: 10534213].
Karim SS, Panton ON, Finley RJ, Graham AJ, Dong S, Storseth C, Clifton J. Comparison of total versus partial laparoscopic fundoplication in themanagement of gastroesophageal reflux disease. May. American Journal of Surgery. 1997;173(5):375-8. Does not meet inclusion criteria. [pmid: 9168069].
Katariya K, Harvey JC, Pina E, Beattie EJ. Complications of transhiatal esophagectomy. Nov. Journal of Surgical Oncology. 1994;57(3):157-63. Intervention not of interest. [pmid: 7967604].
Khoursheed MA, AlAsfoor M, AlShamali M, Ayed AK, Gupta R, Dashti HM, Behbehani AI. Effectiveness of laparoscopic fundoplication for gastro-oesophageal reflux. Jul. Annals of the Royal College of Surgeons of England. 2001;83(4):229-34. Does not meet inclusion criteria. [pmid: 11518368]. [pmcid: 2503365].
Kiroff GK, Maddern GJ, Jamieson GG. A study of factors responsible for the efficacy of fundoplication in the treatment of gastro-oesophageal reflux. Apr. Australian & New Zealand Journal of Surgery. 1984;54(2):109-12. Outcome not of interest. [pmid: 6588948].
Kiviluoto T, Luukkonen P, Salo J. Laparoscopic gastro-oesophageal antireflux surgery. Annales Chirurgiae et Gynaecologiae et Gynaecologiae. 1994;83(2):101-6. Adverse events, available in meta-analysis.
Kiviluoto T, Siren J, Farkkila M, Luukkonen P, Salo J, Kivilaakso E. Laparoscopic Nissen fundoplication: a prospective analysis of 200 consecutive patient. Dec. Surgical Laparoscopy & Endoscopy. 1998;8(6):429-34. Does not meet inclusion criteria. [pmid: 9864109].
Klok RM, Postma MJ, van Hout BA, Brouwers JR. Meta-analysis: comparing the efficacy of proton pump inhibitors in short-term use. [Review] [59 refs]. May. 15 Alimentary Pharmacology & Therapeutics. 2003;17(10):1237-45. Data available in subsequent systematic review. [pmid: 12755837].
Kuster E, Ros E, ToledoPimentel V, Pujol A, Bordas JM, Grande L, Pera C. Predictive factors of the long term outcome in gastro-oesophageal reflux disease: six year follow up of 107 patients. Jan. Gut. 1994;35(1):8-14. Mixed cohort. [pmid: 8307456]. [pmcid: 1374623].
Laheij RJ, van Rossum LG, Verbeek AL, Jansen JB. Helicobacter pylori infection treatment of nonulcer dyspepsia: an analysis of meta-analyses.[comment]. Apr. Journal of Clinical Gastroenterology. 2003;36(4):315-20. Population: non-ulcer dyspepsia; intervention: HP eradication. [pmid: 12642737].
Laine L, Schoenfeld P, Fennerty MB. Therapy for Helicobacter pylori in patients with nonulcer dyspepsia. A meta-analysis of randomized, controlled trials.[see comment]. Mar. 6 Annals of Internal Medicine. 2001;134(5):361-9. Population: non-ulcer dyspepsia; intervention: HP eradication. [pmid: 11242496].
Landreneau RJ, Wiechmann RJ, Hazelrigg SR, Santucci TS, Boley TM, Magee MJ, Naunheim KS. Success of laparoscopic fundoplication for gastroesophageal reflux diseas. Dec. Annals of Thoracic Surgery. 1998;66(6):1886-93. Does not meet inclusion criteria. [pmid: 9930464].
Larrain A, Carrasco E, Galleguillos F, et al. Medical and surgical treatment of nonallergic asthma associated with gastroesophageal reflux. Jun. Chest. 1991;99(6):1330-5. Deals with Asthma. [pmid: 2036812].
Laycock WS, Trus TL, Hunter JG. New technology for the division of short gastric vessels during laparoscopic Nissen fundoplication. A prospective randomized trial. Jan. Surgical Endoscopy. 1996;10(1):71-3. Technique not of interest. [pmid: 8711613].
Leeder PC, Watson DI, Jamieson GG. Laparoscopic fundoplication for patients with symptoms but no objective evidence of gastroesophageal reflux. Diseases of the Esophagus. 2002;15(4):309-14. Does not meet inclusion criteria. [pmid: 12472478].
Leufkens H, Claessens A, Heerdink E, van Eijk J, Lamers CB. A prospective follow-up study of 5669 of lansoprazole in daily practice. Oct. Alimentary Pharmacology & Therapeutics. 1997;11(5):887-97. Available meta-analysis. [pmid: 9354197].
Lochegnies A, Hauters P, Janssen P, Nakad A, Farchack E, Defrennes M. Quality of life assessment after Nissen fundoplication. Jan. Acta Chirurgica Belgica. 2001;101(1):20-4. Does not meet inclusion criteria. [pmid: 11301943].
Lord RV, Huprich JE, Katkhouda N. Images of interest. Gastrointestinal: complications of fundoplication. Oct. Journal of Gastroenterology & Hepatology. 2000;15(10):1221. Case study. [pmid: 11106106].
Ludemann R, Watson DI, Jamieson GG. Influence of follow up methodology and completeness on apparent clinical outcome of fundoplication. Aug. American Journal of Surgery. 2003;186(2):143-7. No Adverse events. [pmid: 12885606].
Lundell L, Dalenback J, Hattlebakk J, Janatuinen E, Levander K, Miettinen P, Myrvold HE, Pedersen SA, Thor K, Junghard O, Andersson A. Outcome of open antireflux surgery as assessed in a Nordic multicentre prospective clinical trial. Nordic GORD-Study Group.[erratum appears in Eur J Surg 1999 Nov;165(11):1104]. Oct. European Journal of Surgery. 1998;164(10):751-7. Follow-up only to 12 mos. [pmid: 9840304].
Lundell LR, Myers JC, Jamieson GG. Delayed gastric emptying and its relationship to symptoms of ‘gas float’ after antireflux surgery. Mar. European Journal of Surgery. 1994;160(3):161-6. Does not meet inclusion criteria. [pmid: 8003568].
Luostarinen M, Virtanen J, Koskinen M, Matikainen M, Isolauri J. Dysphagia and oesophageal clearance after laparoscopic versus open Nissen fundoplication. A randomized, prospective trial. Jun. Scandinavian Journal of Gastroenterology. 2001;36(6):565-71. Follow-up only to 1 yr. [pmid: 11424313].
Luostarinen ME, Isolauri JO. Randomized trial to study the effect of fundic mobilization on long-term results of Nissen fundoplication. [see comment]. May. British Journal of Surgery. 1999;86(5):614-8. Does not meet inclusion criteria. [pmid: 10361180].
Luostarinen ME, Koskinen MO, Isolauri JO. Effect of fundal mobilisation in Nissen-Rossetti fundoplication on oesophageal transit and dysphagia. A prospective, randomised trial. Jan. European Journal of Surgery. 1996;162(1):37-42. Technique not of interest. [pmid: 8679761].
Maher JW, Hocking MP, Woodward ER. Supradiaphragmatic fundoplication. Long-term follow-up and analysis of complications. Jan. American Journal of Surgery. 1984;147(1):181-6. Supra diaphragm fundo. [pmid: 6691545].
Matikainen M. Nissen-Rossetti fundoplication for the treatment of gastro-oesophageal reflux. Acta Chirurgica Scandinavica. 1982;148(2):173-7. Does not meet inclusion criteria. [pmid: 7148314].
Maton PN, Vakil NB, Levine JG, Hwang C, Skammer W, Lundborg P, Esomeprazole S. Safety and efficacy of long term esomeprazole therapy in patients with healed erosive oesophagitis. Drug Safety. 2001;24(8):625-35. Available meta-analysis. [pmid: 11480494].
McDonald ML;Trastek VF;Allen MS;Deschamps C;Pairolero PC;Pairolero PC;Barretts's esophagus: does an antireflux procedure reduce the need for endoscopic surveillance?1996 Jun Journal of Thoracic & Cardiovascular Surgery 111(6):1135–8; discussion 1139–40, Outcome not of interest
McDougall NI, Johnston BT, Collins JS, McFarland RJ, Love AH. Disease progression in gastro-oesophageal reflux disease as determined by repeat oesophageal pH monitoring and endoscopy 3 to 4.5 years after diagnosis. Dec. European Journal of Gastroenterology & Hepatology. 1997;9(12):1161-7. Does not meet inclusion criteria. [pmid: 9471021].
McHardy G;Balart L;Reflux esophagitis in the elderly, with special reference to antacid therapy1972Journal of the American Geriatrics Society Intervention: antacid Tx; tutorial but not SR
McKernan JB, Champion JK. Minimally invasive antireflux surgery. Apr. American Journal of Surgery. 1998;175(4):271-6. Surgical Cohort before 2001 meta-analysis. [pmid: 9568650].
Melvin WS;Needleman BJ;Krause KR;Schneider C;Ellison EC;Computer-enhanced vs. standard laparoscopic antireflux surgery2002 Jan Journal of Gastrointestinal Surgery 6(1):11–5; discussion 15–6, Does not meet inclusion criteria
Menguy R. A modified fundoplication which preserves the ability to belch. Sep. Surgery. 1978;84(3):301-7. Does not meet inclusion criteria. [pmid: 356314].
Mosnier H, Leport J, Aubert A, Kianmanesh R, Sbai Idrissi MS, Guivarc'h M. A 270 degree laparoscopic posterior fundoplasty in the treatment of gastroesophageal reflux. Sep. Journal of the American College of Surgeons. 1995;181(3):220-4. Does not meet inclusion criteria. [pmid: 7670681].
Mossner J, Koop H, Porst H, Wubbolding H, Schneider A, Maier C. One-year prophylactic efficacy and safety of pantoprazole in controlling gastro-oesophageal reflux symptoms in patients with healed reflux oesophagitis. Dec. Alimentary Pharmacology & Therapeutics. 1997;11(6):1087-92. All med tx before systematic review. [pmid: 9663834].
Negre JB;Post-fundoplication symptoms. Do they restrict the success of Nissen fundoplication?1983Annals of Surgery Surgical Cohort before 2001 meta-anlaysis
Negre JB, Markkula HT, Keyrilainen O, Matikainen M. Nissen fundoplication. Results at 10 year follow-up. Nov. American Journal of Surgery. 1983;146(5):635-8. Does not meet inclusion criteria. [pmid: 6638269].
Nelis GF, Engelage AH, Samson G. Does long-term inhibition of gastric acid secretion with omeprazole lead to small intestinal bacterial overgrowth?. Sep. Netherlands Journal of Medicine. 1994;45(3):93-100. All med tx before systematic review. [pmid: 7969669].
O'Rourke IC. Nissen fundoplication for gastro-oesophageal reflux. Oct. Medical Journal of Australia. 1979;2(8):441. Case series. [pmid: 318495].
Orringer MB, Schneider R, Williams GW, Sloan H. Intraoperative esophageal manometry: is it valid?. Jul. Annals of Thoracic Surgery. 1980;30(1):13-8. Not relevant to Q2. [pmid: 7396572].
Oster G, Huse DM, Delea TE, Colditz GA, Richter JM. The risks and benefits of an Rx-to-OTC switch. The case of over-the-counter H2-blockers. Sep. Medical Care. 1990;28(9):834-52. Population: non-ulcer dyspepsia; cost-effective analysis. [pmid: 1976142].
O'sullivan GC, DeMeester TR, Joelsson BE, Smith RB, Blough RR, Johnson LF, Skinner DB. Interaction of lower esophageal sphincter pressure and length of sphincter in the abdomen as determinants of gastroesophageal competence. Jan. American Journal of Surgery. 1982;143(1):40-7. Outcome not of interest. [pmid: 7053654].
Pace F, Bollani S, Molteni P, Bianchi PG. Natural history of gastro-oesophageal reflux disease without oesophagitis (NERD)--a reappraisal 10 years on. Feb. Digestive & Liver Disease. 2004;36(2):111-5. No interventions and prevalence data. [pmid: 15002817].
Papp JP. Determination of the lower esophageal sphincter pressure in patients having a Nissen or Belsey fundoplication. Feb. American Journal of Gastroenterology. 1979;71(2):154-7. Does not meet inclusion criteria. [pmid: 433896].
Parshad R, Kumar MV, Bal S, Saraya A, Sharma MP. Laparoscopic Nissen fundoplication; results of a prospective pilot study. Jul. Tropical Gastroenterology. 2003;24(3):152-6. Does not meet inclusion criteria. [pmid: 14978994].
Patti MG, Feo CV, De Pinto M, Arcerito M, Tong J, Gantert W, Tyrrell D, Way LW. Results of laparoscopic antireflux surgery for dysphagia and gastroesophageal reflux disease. Dec. American Journal of Surgery. 1998;176(6):564-8. Does not meet inclusion criteria. [pmid: 9926791].
Patti MG, Molena D, Fisichella PM, Perretta S, Way LW. Gastroesophageal reflux disease (GERD) and chest pain. Results of laparoscopic antireflux surgery. Apr. Surgical Endoscopy. 2002;16(4):563-6. Age not relevant. [pmid: 11972188].
Peillon C, Manouvrier JL, Labreche J, Kaeffer N, Denis P, Testart J. Should the vagus nerves be isolated from the fundoplication wrap? A prospective study. Aug. Archives of Surgery. 1994;129(8):814-8. Not relevant to Q2. [pmid: 8048850].
Pessaux P, Arnaud JP, Ghavami B, Flament JB, Trebuchet G, Meyer C, Huten N, Champault G. Laparoscopic antireflux surgery: comparative study of Nissen, Nissen-Rossetti, and Toupet fundoplication. Societe Francaise de Chirurgie Laparoscopique. Nov. Surgical Endoscopy. 2000;14(11):1024-7. Does not meet inclusion criteria. [pmid: 11116410].
Peters JH, DeMeester TR, Crookes P, Oberg S, de Vos SM, Hagen JA, Bremner CG. The treatment of gastroesophageal reflux disease with laparoscopic Nissen fundoplication: prospective evaluation of 100 patients with ‘typical’ symptoms. Jul. Annals of Surgery. 1998;228(1):40-50. Does not meet inclusion criteria. [pmid: 9671065]. [pmcid: 1191426].
Peters JH, Silverman DE, Stein A. Lower esophageal sphincter injection of a biocompatible polymer: accuracy of implantation assessed by esophagectomy. Apr. Surgical Endoscopy. 2003;17(4):547-50. Evaluation of location of injection in esophageal resection specimens. [pmid: 12582770].
Pitcher DE;Curet MJ;Martin DT;Castillo RR;Gerstenberger PD;Vogt D;Zucker KA;Successful management of severe gastroesophageal reflux disease with laparoscopic Nissen fundoplication1994 Dec American Journal of Surgery 168(6):547–53; discussion 553–4, Does not meet inclusion criteria
Rabeneck L. Long-term treatment of erosive esophagitis with omeprazole: does it work?. Feb. Gastroenterology. 1995;108(2):613-4. Comment. [pmid: 7835610].
Rabeneck L, Wray NP, Graham DY. Managing dyspepsia: what do we know and what do we need to know?. Jun. American Journal of Gastroenterology. 1998;93(6):920-4. Dyspepsia. [pmid: 9647019].
Rantanen TK, Halme TV, Luostarinen ME, Karhumaki LM, Kononen EO, Isolauri JO. The long term results of open antireflux surgery in a community-based health care center. [see comment]. Jul. American Journal of Gastroenterology. 1999;94(7):1777-81. Outcome not of interest. [pmid: 10406234].
Rantanen TK, Salminen JT, Makinen JE, Sipponen PI, Kiviluoto TA, Salo JA. Clinical significance of esophageal histologic findings after antireflux surgery. Jul. Archives of Surgery. 2001;136(7):733-6. Outcome not of interest. [pmid: 11448380].
Rattner DW;Brooks DC;Patient satisfaction following laparoscopic and open antireflux surgery1995 Mar Archives of Surgery 130(3):289–93; discussion 293–4, Does not meet inclusion criteria
Redstone HA, Barrowman N, Veldhuyzen van Zanten SJ. H2-receptor antagonists in the treatment of functional (nonulcer) dyspepsia: a meta-analysis of randomized controlled clinical trials. Sep. Alimentary Pharmacology & Therapeutics. 2001;15(9):1291-9. Population: non-ulcer dyspepsia. [pmid: 11552898].
Ribet M, Mensier E, Pruvot FR. Barrett's esophagus and adenocarcinoma. European Journal of Cardio-Thoracic Surgery. 1987;1(1):29-32. Outcome not of interest. [pmid: 3273209].
Richards WO, Scholz S, Khaitan L, Sharp KW, Holzman MD. Initial experience with the stretta procedure for the treatment of gastroesophageal reflux disease. Oct. Journal of Laparoendoscopic & Advanced Surgical Techniques-Part A. 2001;11(5):267-73. Duplicate of Houston paper. [pmid: 11642661].
Richardson JD;Kuhns JG;Richardson RL;Polk HC;Properly conducted fundoplication reverses histologic evidence of esophagitis1983Annals of Surgery Does not meet inclusion criteria
Rogers DM;Herrington JL;Morton C;Incidental splenectomy associated with Nissen fundoplication1980Annals of Surgery Adverse events, before 1997
Rydberg L, Ruth M, Lundell L. Characteristics of secondary oesophageal peristalsis in operated and non-operated patients with chronic gastro-oesophageal reflux disease. Jul. European Journal of Gastroenterology & Hepatology. 2000;12(7):739-43. Outcome not of interest. [pmid: 10929899].
Sandbu R, Khamis H, Gustavsson S, Haglund U. Long-term results of antireflux surgery indicate the need for a randomized clinical trial. Feb. British Journal of Surgery. 2002;89(2):225-30. Does not meet inclusion criteria. [pmid: 11856139].
Schenk BE, Festen HP, Kuipers EJ, KlinkenbergKnol EC, Meuwissen SG. Effect of short- and long-term treatment with omeprazole on the absorption and serum levels of cobalamin. Aug. Alimentary Pharmacology & Therapeutics. 1996;10(4):541-5. Outcome not of interest. [pmid: 8853757].
Schumacher MC, Jick SS, Jick H, Feld AD. Cimetidine use and gastric cancer. May. Epidemiology. 1990;1(3):251-4. All med tx before systematic review. [pmid: 2081261].
Sharma VK, Leontiadis GI, Howden CW. Meta-analysis of randomized controlled trials comparing standard clinical doses of omeprazole and lansoprazole in erosive oesophagitis. Feb. Alimentary Pharmacology & Therapeutics. 2001;15(2):227-31. Limited individual comparisons (only lansoprazole vs. omeprazole). [pmid: 11148442].
Shirazi SS, Schulze K, Soper RT. Long-term follow-up for treatment of complicated chronic reflux esophagitis. May. Archives of Surgery. 1987;122(5):548-52. Cohort before 1995. [pmid: 3579565].
Simon TJ, Bradstreet DC. Comparative tolerability profile of omeprazole in clinical trials. Oct. Digestive Diseases & Sciences. 1991;36(10):1384-9. All med tx before systematic review. [pmid: 1914759].
Slim K, Bousquet J, Kwiatkowski F, Lescure G, Pezet D, Chipponi J. Quality of life before and after laparoscopic fundoplication. Jul. American Journal of Surgery. 2000;180(1):41-5. Does not meet inclusion criteria. [pmid: 11036138].
So JB, Zeitels SM, Rattner DW. Outcomes of atypical symptoms attributed to gastroesophageal reflux treated by laparoscopic fundoplication. Jul. Surgery. 1998;124(1):28-32. Population not of interest. [pmid: 9663248].
Solcia E, Fiocca R, Havu N, Dalvag A, Carlsson R. Gastric endocrine cells and gastritis in patients receiving long-term omeprazole treatment. Digestion. 1992;51(Suppl 1):82-92. All med tx before systematic review. [pmid: 1397749].
Solcia E;Rindi G;Havu N;Elm G;Qualitative studies of gastric endocrine cells in patients treated long-term with omeprazole1989Scandinavian Journal of Gastroenterology - Supplement 166;129–37; discussion 138–9, Available in subsequent meta-analysis
Solvell L;The clinical safety of omeprazole1989Scandinavian Journal of Gastroenterology - Supplement 166;106–10; discussion 111–3, Available in subsequent meta-analysis
Sonnenberg A. Motion--Laparoscopic Nissen fundoplication is more cost effective than oral PPI administration arguments against the motion. Sep. Canadian Journal of Gastroenterology. 2002;16(9):627-31. Population non-ulcer dyspepsia. [pmid: 12362217].
Soper NJ;Dunnegan D;Anatomic fundoplication failure after laparoscopic antireflux surgery1999 May Annals of Surgery 229(5);669–76; discussion 676–7, Does not meet inclusion criteria
Spechler SJ, Jain SK, Tendler DA, Parker RA. Racial differences in the frequency of symptoms and complications of gastro-oesophageal reflux disease.[see comment]. Oct. Alimentary Pharmacology & Therapeutics. 2002;16(10):1795-800. Available in subsequent meta-analysis. [pmid: 12269973].
Starnes VA, Adkins RB, Ballinger JF, Sawyers JL. Barrett's esophagus. A surgical entity. May. Archives of Surgery. 1984;119(5):563-7. Outcome not of interest. [pmid: 6712469].
Stein HJ;Feussner H;Siewert JR;Failure of antireflux surgery causes and management strategies1996 Jan American Journal of Surgery 171(1);36–9; discussion 39–40, Outcome not of interest
Stirling MC, Orringer MB. Surgical treatment after the failed antireflux operation. Oct. Journal of Thoracic & Cardiovascular Surgery. 1986;92(4):667-72. Intervention not of interest. [pmid: 3762198].
Straathof JW, Ringers J, Masclee AA. Prospective study of the effect of laparoscopic Nissen fundoplication on reflux mechanisms. Nov. British Journal of Surgery. 2001;88(11):1519-24. Does not meet inclusion criteria. [pmid: 11683752].
Swanstrom LL, Pennings JL. Laparoscopic control of short gastric vessels. Oct. Journal of the American College of Surgeons. 1995;181(4):347-51. Does not meet inclusion criteria. [pmid: 7551329].
Talley NJ, Lauritsen K. The potential role of acid suppression in functional dyspepsia the BOND, OPERA, PILOT, and ENCORE studies. May. Gut. 2002;50 Suppl 4:iv36-41. Population not of interest. [pmid: 11953346].
Tardif C, Nouvet G, Denis P, Tombelaine R, Pasquis P. Surgical treatment of gastroesophageal reflux in ten patients with severe asthma. Respiration. 1989;56(12):110-5. Extra esophageal GERD. [pmid: 2602664].
Tew S, Ackroyd R, Jamieson GG, Holloway RH. Belching and bloating facts and fantasy after antireflux surgery. Apr. British Journal of Surgery. 2000;87(4):477-81. Outcome not of interest. [pmid: 10759746].
Tew S, Jamieson GG, Holloway RH, Ferguson S, Tew P. A prospective study of the effect of fundoplication on primary and secondary peristalsis in the esophagus. Oct. Diseases of the Esophagus. 1997;10(4):247-52. Does not meet inclusion criteria. [pmid: 9455651].
Thor KB, Silander T. A long-term randomized prospective trial of the Nissen procedure versus a modified Toupet technique. Dec. Annals of Surgery. 1989;210(6):719-24. Does not meet inclusion criteria. [pmid: 2686567]. [pmcid: 1357862].
Torquati A, Houston HL, Kaiser J, Holzman MD, Richards WO. Long-term follow-up study of the Stretta procedure for the treatment of gastroesophageal reflux diseases. Oct. Surgical Endoscopy. 2004;18(10):1475-9. Same patients reported with longer follow-up in Lutfu 2005. [pmid: 15791372].
Tseng EE;Wu TT;Yeo CJ;Heitmiller RF;Barrett's esophagus with high grade dysplasia: surgical results and long-term outcome--an update2003 Feb Journal of Gastrointestinal Surgery 7(2):164–70; discussion 170–1, Outcome not of interest
Tucker JG, Ramshaw BJ, Newman CL, Sims MS, Mason EM, Duncan TD, Lucas GW. Laparoscopic fundoplication in the treatment of severe gastroesophageal reflux disease preliminary results of a prospective trial. Jan. Southern Medical Journal. 1996;89(1):60-4. Does not meet inclusion criteria. [pmid: 8545694].
Urschel JD. Gastroesophageal leaks after antireflux operations. May. Annals of Thoracic Surgery. 1994;57(5):1229-32. Data available in subsequent meta-analysis. [pmid: 8179390].
van Rensburg CJ, Honiball PJ, van Zyl JH, Grundling HD, Eloff FP, Spies SK, Simjee AE, Theron I, Fischer R, Louw JA. Safety and efficacy of pantoprazole 40 mg daily as relapse prophylaxis in patients with healed reflux oesophagitis-a 2-year follow-up. Aug. Alimentary Pharmacology & Therapeutics. 1999;13(8):1023-8. Available meta-analysis. [pmid: 10468676].
Varga G, Kiraly A, Moizs M, Horvath OP. Effect of laparoscopic antireflux operation on esophageal manometry, 24 hours pH-metry and quality of life in gastroesophageal reflux diseases. Acta Chirurgica Hungarica. 1999;38(2):213-8. Does not meet inclusion criteria. [pmid: 10596333].
Velanovich V;Comparison of symptomatic and quality of life outcomes of laparoscopic versus open antireflux surgery1999 Oct Surgery 126(4);782–8; discussion 788–9, Does not meet inclusion criteria
Velanovich V. Medication usage and additional esophageal procedures after antireflux surgery. Jun. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2003;13(3):161-4. Patients included with typical and atypical symptoms results were not separately reported.
Veldhuyzen van Zanten SJ, Cleary C, Talley NJ, Peterson TC, Nyren O, Bradley LA, Verlinden M, Tytgat GN. Drug treatment of functional dyspepsia a systematic analysis of trial methodology with recommendations for design of future trials.[see comment]. Apr. American Journal of Gastroenterology. 1996;91(4):660-73. Population not of interest. [pmid: 8677926].
Helicobacter pylori lead to sustained improvement in functional dyspepsia symptoms?2002 May Gut 50 Suppl 4;iv26–30 discussion iv31–2, Population not of interest
Viljakka M, Nevalainen J, Isolauri J. Lifetime costs of surgical versus medical treatment of severe gastro-oesophageal reflux disease in Finland. Aug. Scandinavian Journal of Gastroenterology. 1997;32(8):766-72. Outcome not of interest. [pmid: 9282967].
Viljakka M, Saali K, Koskinen M, Karhumaki L, Kossi J, Luostarinen M, Teerenhovi O, Isolauri J. Antireflux surgery enhances gastric emptying. Jan. Archives of Surgery. 1999;134(1):18-21. Does not meet inclusion criteria. [pmid: 9927124].
Washer GF, Gear MW, Dowling BL, Gillison EW, Royston CM, Spencer J. Duodenal diversion with vagotomy and antrectomy for severe or recurrent reflux oesophagitis and stricture an alternative to operation at the hiatus. Jul. Annals of the Royal College of Surgeons of England. 1986;68(4):222-6. Intervention not of interest. [pmid: 3789611]. [pmcid: 2498392].
Watson A, Spychal RT, Brown MG, Peck N, Callander N. Laparoscopic ‘physiological’ antireflux procedure preliminary results of a prospective symptomatic and objective study. May. British Journal of Surgery. 1995;82(5):651-6. Does not meet inclusion criteria. [pmid: 7613942].
Watson DI, Pike GK, Baigrie RJ, Mathew G, Devitt PG, Britten Jones R, Jamieson GG. Prospective double-blind randomized trial of laparoscopic Nissen fundoplication with division and without division of short gastric vessels. Nov. Annals of Surgery. 1997;226(5):642-52. Does not meet inclusion criteria. [pmid: 9389398]. [pmcid: 1191126].
Wetscher GJ, Glaser K, Wieschemeyer T, Gadenstaetter M, Prommegger R, Profanter C. Tailored antireflux surgery for gastroesophageal reflux disease effectiveness and risk of postoperative dysphagia. Jul. World Journal of Surgery. 1997;21(6):605-10. Does not meet inclusion criteria. [pmid: 9230657].
Wilton LV, Key C, Shakir SA. The pharmacovigilance of pantoprazole the results of postmarketing surveillance on 11 541 patients in England. Drug Safety. 2003;26(2):121-32. Data available in subsequent systematic review. [pmid: 12534328].
Winslow ER, Clouse RE, Desai KM, Frisella P, Gunsberger T, Soper NJ, Klingensmith ME. Influence of spastic motor disorders of the esophageal body on outcomes from laparoscopic antireflux surgery. May. Surgical Endoscopy. 2003;17(5):738-45. Outcome not of interest. [pmid: 12618949].
Wong WM, Lai KC, Lam KF, Hui WM, Hu WH, Lam CL, Xia HH, Huang JQ, Chan CK, Lam SK, Wong BC. Prevalence, clinical spectrum and health care utilization of gastro-oesophageal reflux disease in a Chinese population a population-based study.[see comment]. Sep. 15 Alimentary Pharmacology & Therapeutics. 2003;18(6):595-604. Outcome not of interest. [pmid: 12969086].
Wykypiel H, Wetscher GJ, Klaus A, Schmid T, Gadenstaetter M, Bodner J, Bodner E. Robot-assisted laparoscopic partial posterior fundoplication with the DaVinci system initial experiences and technical aspects. Feb. Langenbecks Archives of Surgery. 2003;387(1112):411-6. Does not meet inclusion criteria.
Yau P, Watson DI, Devitt PG, Game PA, Jamieson GG. Laparoscopic antireflux surgery in the treatment of gastroesophageal reflux in patients with Barrett esophagus. Jul. Archives of Surgery. 2000;135(7):801-5. Outcome not of interest. [pmid: 10896373].
Zaninotto G, Anselmino M, Costantini M, Boccu C, Ancona E. Laparoscopic treatment of gastro-esophageal reflux disease indications and results. Oct. International Surgery. 1995;80(4):380-5. Does not meet inclusion criteria. [pmid: 8740690].
Zaninotto G, Costantini M, Anselmino M, Boccu C, Bagolin F, Polo R, Ancona E. Excessive competence of the lower oesophageal sphincter after Nissen fundoplication evaluation by three-dimensional computerised imaging. Apr. European Journal of Surgery. 1995;161(4):241-6. Outcome not of interest. [pmid: 7612765].
Zeitoun P;Comparison of omeprazole with ranitidine in the treatment of reflux oesophagitis1989Scandinavian Journal of Gastroenterology - Supplement 16683–7; discussion 94, Data available in subsequent systematic review
Zugel N, Jung C, Bruer C, Sommer P, Breitschaft K. A comparison of laparoscopic Toupet versus Nissen fundoplication in gastroesophageal reflux disease. Jan. Langenbecks Archives of Surgery. 2002;386(7):494-8. Does not meet inclusion criteria.