# Search strategy

## Search strategy

1 exp Gastroesophageal Reflux
2 gastro-esophageal reflux.tw.
3 gastro-esophageal reflux.tw.
4 gastro-oesophageal reflux.tw.
5 exp esophagitis
6 esophagitis.tw.
7 oesophagitis.tw.
8 (GERD or GORD).tw.
9 bile reflux
10 heartburn
11 heartburn.tw.
12 (acid adj5 reflux).tw.
13 exp dyspepsia
14 dyspep$.tw.
15 or/1–14
16 limit 15 to human
17 limit 16 to english language
18 limit 17 to adult
19 17 not 18
20 limit 19 to child
21 17 not 20
22 follow-up studies
23 (follow-up or followup).tw.
24 exp cohort studies
25 cohort.tw.
26 exp Case-Control Studies
27 (case adj20 control).tw.
28 exp Longitudinal Studies
29 longitudinal.tw.
30 (random$ or rct).tw.
31 exp Randomized Controlled Trials
32 exp random allocation
33 exp Double-Blind Method
34 exp Single-Blind Method
35 randomized controlled trial.pt.
36 clinical trial.pt.
37 controlled clinical trials
38 (clin$ adj trial$).tw.
39 ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
40 exp Research Design
41 exp Evaluation Studies
42 exp Prospective Studies
43 exp Comparative Study
44 or/22–41
45 21 and 44
46 limit 45 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index)
47 45 not 46
48 limit 47 to (guideline or meta analysis or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial)
49 47 not 48
50 dt.fs.
51 su.fs.
52 49 and (50 and 51)
53 49 not 52
54 53 and 51
55 53 not 54
56 55 and 50
57 55 not 56
58 th.fs.
59 57 and 58
60 57 not 59
61 co.fs.
62 60 and 61
63 60 not 62
64 limit 63 to “all adult (19 plus years)”
65 exp Gastroesophageal Reflux
66 gastro-esophageal reflux.tw.
67 gastro-esophageal reflux.tw.
68 gastro-oesophageal reflux.tw.
69 exp esophagitis
70 esophagitis.tw.
71 oesophagitis.tw.
72 (GERD or GORD).tw.
73 bile reflux
74 heartburn
75 heartburn.tw.
76 (acid adj5 reflux).tw.
77 exp dyspepsia
78 dyspep$.tw.
79 or/65–78
80 limit 79 to human
81 limit 80 to english language
82 limit 81 to “all adult (19 plus years)”
83 81 not 82
84 limit 83 to “all child (0 to 18 years)”
85 81 not 84
86 follow-up studies
87 (follow-up or followup).tw.
88 exp cohort studies
89 cohort.tw.
90 exp Case-Control Studies
91 (case adj20 control).tw.
92 exp Longitudinal Studies
93 longitudinal.tw.
94 (random$ or rct).tw.
95 exp Randomized Controlled Trials
96 exp random allocation
97 exp Double-Blind Method
98 exp Single-Blind Method
99 randomized controlled trial.pt.
100 clinical trial.pt.
101 controlled clinical trials
102 (clin$ adj trial$).tw.
103 ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
104 exp Research Design
105 exp Evaluation Studies
106 exp Prospective Studies
107 exp Comparative Study
108 or/86–105
109 85 and 108
110 limit 109 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index)
111 109 not 110
112 limit 111 to (guideline or meta analysis or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial)
113 111 not 112
114 dt.fs.
115 su.fs.
116 113 and (114 and 115)
117 113 not 116
118 117 and 115
119 117 not 118
120 119 and 114
121 119 not 120
122 th.fs.
123 121 and 122
124 121 not 123
125 co.fs.
126 124 and 125
127 124 not 126
128 from 127 keep 1