# Appendixes

Appendix A Search strategy

Appendix B List of Excluded Studies

Appendix C Evidence Tables

Appendix D Peer Reviewers

Appendix E Common Esophagitis Grading Scales

Appendix F Description of Endoscopic Treatments and Preliminary Findings

Appendix G Gastroesophageal Reflux Disease-Health-Related Quality-of-Life Scale