# Working Papers

Working papers, discussion papers, and occasional papers report original research in a narrow area of study. They sometimes are used to communicate new approaches or ideas, or to solicit comment from other scholars. NLM selectively acquires working papers, emphasizing notable series in health economics, health services research, and health policy.

## See also

Technical Reports