# Urology

Definition

The branch of medicine concerned with the study, diagnosis, and treatment of diseases of the urinary tract in both sexes, and the genital tract in the male (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D014572)).

Discussion

Urology includes andrology, the study of male genital diseases and male fertility.

Scope and emphasis

Collected comprehensively.

## See also

Nephrology