# Translations

NLM collects works in the original language, and also acquires translations from foreign languages into English.

Translations from one foreign language into another, or from English into another language, are rarely acquired. They may be selected if they have important scholarly apparatus such as extensive commentary, represent a significant work that the Library does not possess in its original language; are the only known medical work available in that language; or are translated from a language that is not well known in the United States to a language that is clearly better known (e.g., Vietnamese to French) provided that no English translation is available.

When works are issued simultaneously in several languages, NLM generally collects the English version only. There are exceptions. For example, the Library occasionally collects examples of works intended for international public health outreach in several languages, especially languages where few medical works appear (e.g., Pashto).