# Therapeutics

Definition

The plan of treatment of a disease or disorder as administered by a health care practitioner.

Scope and emphasis

NLM collects works on current and historical systems of therapeutics. Preference is given to works prepared for health care professionals including practitioners of complementary and alternative health care systems. Works that provide a detailed description of the therapeutics system or include a critical history or analysis of the system also may be selected.

## See also

Complementary and Alternative Medicine