# Tests

NLM generally does not collect individual tests which measure, diagnose, or evaluate psychological or physical processes or status. The NLM collection includes an extensive collection of literature about tests and testing.