# Surgery

Definition

The branch of medicine in which manual or operative procedures are used in the diagnosis and treatment of disease, injuries, or deformities.

Discussion

Specialties include neurological, orthopaedic, plastic, thoracic, and colon and rectal surgery.

Scope and emphasis

Collected comprehensively.

Special considerations

Still and moving images depicting surgical techniques are of particular interest. NLM has an extensive historical collection in surgery and holds the papers of several key surgical organizations.