# Still Image Media

Consisting of photographs, posters, maps, fine art, ephemera such as patent medicine trade cards, and more, these still image media document visually the history and development of medicine from antiquity through the early 21^st^ century, serving to:

- illustrate changing cultural, political, and social aspects of medicine;
- depict health professionals and biomedical scientists who have contributed to the development of medicine, as well as health institutions such as hospitals and medical schools;
- communicate public health messages, such as in the contexts of AIDS, preventive medicine, maternal and child health, and occupational health;
- advertise health-related services;
- show and explain human anatomy, such as anatomical atlases;
- and reflect developments in health care and official responses to health crises.

## See also

Ephemera