# Statistical Works

This category includes works that tabulate and summarize data.

NLM collects significant statistical works in all areas of health and biomedicine. Of particular interest are works that report vital statistics, disease incidence, health status indicators, health outcomes, and factors that have a direct impact on health and medical research. Emphasis is on cumulated works that are national or international in scope, cumulations of U.S. state health and vital statistics, statistical works that describe populations of special epidemiological interest, and statistical works from any jurisdiction that include substantial scholarly interpretation and analysis.

## See also

Datasets